# Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report by the peer reviewers.

- Scott Gilbert, MD
- Assistant Professor of Medicine
- Director, Kidney and Blood Pressure Center
- Tufts-New England Medical Center
- Boston, Massachusetts

- Linda Humphrey, MD, MPH
- Scientific Resource Center
- Oregon Health and Science University
- Portland, Oregon

- Timothy Murphy, MD
- Professor, Diagnostic Imaging
- Brown University School of Medicine
- Medical Director, Vascular Disease Research Center
- Rhode Island Hospital
- Providence, Rhode Island

- Wayne Powell
- Senior Director for Advocacy and Guidelines
- Society for Cardiovascular Angiography and Interventions (SCAI)

- John H. Rundback, MD
- Associate Professor of Clinical Radiology
- College of Physicians and Surgeons of Columbia University
- New York, NewYork

- Stephen C. Textor, M.D.
- Division of Nephrology
- Department of Medicine
- Mayo Clinic, Rochester, Minnesota

- Katherine R. Tuttle, MD
- Director of Research
- The Heart Institute of Spokane
- Spokane, Washington

- I. David Weiner, MD
- Division of Nephrology, Hypertension and Transplantation
- University of Florida College of Medicine
- Chief, Nephrology and Hypertension Section
- Gainesville, Florida

- Christopher J. White, MD, FSCAI
- Chairman, Department of Cardiology, Ochsner Heart and Vascular Institute, New Orleans, Louisiana

- R. Eugene Zierler, MD
- Professor of Surgery
- Division of Vascular Surgery
- University of Washington
- Seattle, Washington

- Robert Zwolak, MD, PhD
- Division of Vascular Surgery
- Dartmouth-Hitchcock Medical Center
- New Hampshire

Drs. Gilbert, Rundback, Textor and Tuttle were also members of the EPC’s Technical Expert Panel for the original CER