# Excluded Studies

Cianci R, Coen G, Manfredini P et al. Diagnosis and outcome of renal function in patients with renal artery stenosis: which role have color Doppler sonography and magnetic resonance angiography? Minerva Cardioangiologica. 2006;54:139–144.

Diagnosis of RAS only

Cooper CJ, Murphy TP, Matsumoto A et al. Stent revascularization for the prevention of cardiovascular and renal events among patients with renal artery stenosis and systolic hypertension: rationale and design of the CORAL trial. American Heart Journal. 2006;152:59–66.

Study design only

Edwards MS, Corriere MA, Craven TE et al. Atheroembolism during percutaneous renal artery revascularization. Journal of Vascular Surgery. 2007;46:55–61.

N<30 (PTRA study)

Hanzel G, Balon H, Wong O, Soffer D, Lee DT, Safian RD. Prospective evaluation of aggressive medical therapy for atherosclerotic renal artery stenosis, with renal artery stenting reserved for previously injured heart, brain, or kidney. American Journal of Cardiology. 2005;96:1322–1327.

Already included in original CER

Kalra PA, Guo H, Kausz AT et al. Atherosclerotic renovascular disease in United States patients aged 67 years or older: risk factors, revascularization, and prognosis. Kidney International. 2005;68:293–301.

Retrospective (PTRA study)

Kashyap VS, Sepulveda RN, Bena JF et al. The management of renal artery atherosclerosis for renal salvage: does stenting help? Journal of Vascular Surgery. 2007;45:101–108.

Retrospective (PTRA study)

Kennedy DJ, Burket MW, Khuder SA, Shapiro JI, Topp RV, Cooper CJ. Quality of life improves after renal artery stenting. Biological Research for Nursing. 2006;8:129–137.

Cross-sectional study

Mitchell JA, Subramanian R, White CJ et al. Predicting blood pressure improvement in hypertensive patients after renal artery stent placement: renal Fractional Flow Reserve. Catheterization & Cardiovascular Interventions. 2007;69:685–689.

N<30 (PTRA study)

Muller-Hulsbeck S, Frahm C, Behm C et al. Low-profile stent placement with the monorail technique for treatment of renal artery stenosis: midterm results of a prospective trial. Journal of Vascular & Interventional Radiology. 2005;16:963–971.

N<30 analyzed (PTRA study)

Murphy TP, Cooper CJ, Dworkin LD et al. The Cardiovascular Outcomes with Renal Atherosclerotic Lesions (CORAL) study: rationale and methods. Journal of Vascular & Interventional Radiology. 2005;16:1295–1300.

Study design only

Pearce JD, Craven BL, Craven TE et al. Progression of atherosclerotic renovascular disease: A prospective population-based study. Journal of Vascular Surgery. 2006;44:955–962.

No outcomes of interest

Rivolta R, Bazzi C, Stradiotti P, Paparella M. Stenting of renal artery stenosis: is it beneficial in chronic renal failure? Journal of Nephrology. 2005;18:749–754.

Already included in original CER

Rocha-Singh K, Jaff MR, Rosenfield K, Trial I. Evaluation of the safety and effectiveness of renal artery stenting after unsuccessful balloon angioplasty: the ASPIRE-2 study.[see comment]. Journal of the American College of Cardiology. 2005;46:776–783.

Already included in original CER

Rocha-Singh KJ, Ahuja RK, Sung CH, Rutherford J. Long-term renal function preservation after renal artery stenting in patients with progressive ischemic nephropathy. Catheterization & Cardiovascular Interventions. 2002;57:135–141.

Retrospective (PTRA study)

Scarpioni R, Michieletti E, Cristinelli L et al. Atherosclerotic renovascular disease: medical therapy versus medical therapy plus renal artery stenting in preventing renal failure progression: the rationale and study design of a prospective, multicenter and randomized trial (NITER). Journal of Nephrology. 2005;18:423–428.

Study design only