# Search Strategy

## Database: MEDLINE 1996-April Week 4 2007

# | Search History
1 | exp Hypertension, Renal/
2 | exp Renal Artery Obstruction/
3 | renal arter$ stenosis.tw.
4 | renal arter$ dis$.tw.
5 | renovascular dis$.tw.
6 | reno vascular dis$.tw.
7 | renal vascular dis$.tw.
8 | (arvd or “atherosclerotic renovascular dis$”).tw.
9 | renal steno$.tw.
10 | steno$ kidney.tw.
11 | renovascular steno$.tw.
12 | or/1–11
13 | limit 12 to humans
14 | limit 13 to english language limit 14 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or
15 | editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or “review of reported cases”)
16 | 14 not 15
17 | [limit to MEDLINE entry dates August 2005 to April 23, 2007]