# Appendixes

Appendix A Search Strategy

Appendix B Excluded Studies

Appendix C Peer Reviewers

Appendix D Supplemental Tables and Figure