# References

1 Safian RD, Textor SC. Renal-artery stenosis. N Engl J Med. 2001;344(6):431-442. [pmid: 11172181].
2 Harding MB, Smith LR, Himmelstein SI, et al. Renal artery stenosis: prevalence and associated risk factors in patients undergoing routine cardiac catheterization. J Am Soc Nephrol. 1992;2(11):1608-1616. [pmid: 1610982].
3 Missouris CG, Buckenham T, Cappuccio FP, MacGregor GA. Renal artery stenosis: a common and important problem in patients with peripheral vascular disease. Am J Med. 1994;96(1):10-14. [pmid: 8304356].
4 United States Renal Data System (USRDS). 1997 Annual Data Report. Bethesda, Maryland. US Department of Health and Human Services/National Institutes of Health/National Institute of Diabetes and Digestive and Kidney Diseases. 1997.
5 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-2572. [pmid: 12748199].
6 Taylor AT Jr, Fletcher JW, Nally JV Jr, et al. Procedure guideline for diagnosis of renovascular hypertension. Society of Nuclear Medicine. J Nucl Med. 1998;39(7):1297-1302. [pmid: 9669414].
7 Clinical practice guideline on hypertension and antihypertensive agents in chronic kidney disease. Am J Kidney Dis. 2004;43(5). Suppl 1. [pmid: 15114537].
8 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic). J Am Coll Cardiol. 2006;47(6):1239-1312. [pmid: 16545667].
9 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic). Circulation. 2006;113(11):e463-e654. [pmid: 16549646].
10 Rundback JH, Sacks D, Kent KC, et al. Guidelines for the reporting of renal artery revascularization in clinical trials. American Heart Association. Circulation. 2002;106(12):1572-1585. [pmid: 12234967].
11 Murphy TP, Soares G, Kim M. Increase in utilization of percutaneous renal artery interventions by medicare beneficiaries, 1996–2000. AJR Am J Roentgenol. 2004;183(3):561-568. [pmid: 15333335].
12 ClinicalTrials.gov. Benefits of Medical Therapy Plus Stenting for Renal Atherosclerotic Lesions. 2006. April 3, 2006. http://www.clinicaltrials.gov/ct/show/NCT00081731.
13 Balk E, Chung M, Chew P, et al. Effects of Soy on Health Outcomes. Evidence Report/Technology Assessment No. 126 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 05-E024-2. 2005. Rockville, MD. Agency for Healthcare Research and Quality.
14 K/DOQI clinical practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Kidney Disease Outcome Quality Initiative. Am J Kidney Dis. 2002;39(2:Suppl 2):S1-S246. [pmid: 11904577].
15 van Jaarsveld BC, Krijnen P. Prospective studies of diagnosis and intervention: the Dutch experience. Semin Nephrol. 2000;20(5):463-473. [pmid: 11022900].
16 van Jaarsveld BC, Krijnen P, Pieterman H, et al. The effect of balloon angioplasty on hypertension in atherosclerotic renal-artery stenosis. Dutch Renal Artery Stenosis Intervention Cooperative Study Group. N Engl J Med. 2000;342(14):1007-1014. [pmid: 10749962].
17 Krijnen P, van Jaarsveld BC, Deinum J, Steyerberg EW, Habbema JD. Which patients with hypertension and atherosclerotic renal artery stenosis benefit from immediate intervention?. J Hum Hypertens. 2004;18(2):91-96. [pmid: 14730323].
18 Webster J, Marshall F, Abdalla M, et al. Randomised comparison of percutaneous angioplasty vs continued medical therapy for hypertensive patients with atheromatous renal artery stenosis. Scottish and Newcastle Renal Artery Stenosis Collaborative Group. J Hum Hypertens. 1998;12(5):329-335. [pmid: 9655655].
19 Plouin PF, Chatellier G, Darne B, Raynaud A. Blood pressure outcome of angioplasty in atherosclerotic renal artery stenosis: a randomized trial. Essai Multicentrique Medicaments vs Angioplastie (EMMA) Study Group. Hypertension. 1998;31(3):823-829. [pmid: 9495267].
20 Pizzolo F, Mansueto G, Minniti S, et al. Renovascular disease: effect of ACE gene deletion polymorphism and endovascular revascularization. J Vasc Surg. 2004;39(1):140-147. [pmid: 14718831].
21 Pillay WR, Kan YM, Crinnion JN, Wolfe JH, Joint Vascular Research Group. Prospective multicentre study of the natural history of atherosclerotic renal artery stenosis in patients with peripheral vascular disease. Br J Surg. 2002;89(6):737-740. [pmid: 12027983].
22 Uzzo RG, Novick AC, Goormastic M, Mascha E, Pohl M. Medical versus surgical management of atherosclerotic renal artery stenosis. Transplant Proc. 2002;34(2):723-725. [pmid: 12009679].
23 Johansson M, Herlitz H, Jensen G, Rundqvist B, Friberg P. Increased cardiovascular mortality in hypertensive patients with renal artery stenosis. Relation to sympathetic activation, renal function and treatment regimens. J Hypertens. 1999;17(12 Pt 1):1743-1750. [pmid: 10658941].
24 Englund R, Brown MA. Renal angioplasty for renovascular disease: a reappraisal. J Cardiovasc Surg (Torino). 1991;32(1):76-80.
25 Taylor DC, Moneta GL, Strandness DE Jr. Follow-up of renal artery stenosis by duplex ultrasound. J Vasc Surg. 1989;9(3):410-415. [pmid: 2522152].
26 Nordmann AJ, Logan AG. Balloon angioplasty versus medical therapy for hypertensive patients with renal artery obstruction. Cochrane Database Syst Rev. 2003;(3):CD002944.
27 Nordmann AJ, Woo K, Parkes R, Logan AG. Balloon angioplasty or medical therapy for hypertensive patients with atherosclerotic renal artery stenosis? A meta-analysis of randomized controlled trials. Am J Med. 2003;114(1):44-50. [pmid: 12557864].
28 Hanzel G, Balon H, Wong O, et al. Prospective evaluation of aggressive medical therapy for atherosclerotic renal artery stenosis, with renal artery stenting reserved for previously injured heart, brain, or kidney. Am J Cardiol. 2005;96(9):1322-1327. [pmid: 16253607].
29 Franklin SS, Smith RD. Comparison of effects of enalapril plus hydrochlorothiazide versus standard triple therapy on renal function in renovascular hypertension. Am J Med. 1985;79(3C):14-23. [pmid: 2996342].
30 Franklin SS, Smith RD. A comparison of enalapril plus hydrochlorothiazide with standard triple therapy in renovascular hypertension. Nephron. 1986;44(Suppl 1):73-82. [pmid: 3018602].
31 Ogihara T, Kaneko Y, Ikeda M, et al. Clinical evaluation of delapril in Japan. Report from the Japan Study Group on Delapril. Am J Hypertens. 1991;4(1 Pt 2):42S-45S. [pmid: 2009147].
32 Tillman DM, Malatino LS, Cumming AM, et al. Enalapril in hypertension with renal artery stenosis: long-term follow-up and effects on renal function. J Hypertens Suppl. 1984;2(2):S93-S100. [pmid: 6100883].
33 Takabatake T, Ohta H, Yamamoto Y, et al. Effect of angiotensin blockade and converting enzyme inhibition on renovascular hypertension: comparison between unilateral and bilateral renal artery stenosis. Angiology. 1987;38(6):434-439. [pmid: 3035964].
34 Jackson B, Murphy BF, Johnston CI, KincaidSmith P, Whitworth JA. Renovascular hypertension: treatment with the oral angiotensin-converting enzyme inhibitor enalapril. Am J Nephrol. 1986;6(3):182-186. [pmid: 3017107].
35 Jackson B, McGrath BP, Matthews PG, Wong C, Johnston CI. Differential renal function during angiotensin converting enzyme inhibition in renovascular hypertension. Hypertension. 1986;8(8):650-654. [pmid: 3015794].
36 Hricik DE, Browning PJ, Kopelman R, et al. Captopril-induced functional renal insufficiency in patients with bilateral renal-artery stenoses or renal-artery stenosis in a solitary kidney. N Engl J Med. 1983;308(7):373-376. [pmid: 6337327].
37 Caps MT, Zierler RE, Polissar NL, et al. Risk of atrophy in kidneys with atherosclerotic renal artery stenosis. Kidney Int. 1998;53(3):735-742. [pmid: 9507221].
38 Conlon PJ, Little MA, Pieper K, Mark DB. Severity of renal vascular disease predicts mortality in patients undergoing coronary angiography. Kidney Int. 2001;60(4):1490-1497. [pmid: 11576364].
39 Fergany A, Novick AC, Goldfarb DA. Management of atherosclerotic renal artery disease in younger patients. J Urol. 1994;151(1):10-12. [pmid: 8254782].
40 Houston JG, Gandy SJ, Milne W, et al. Spiral laminar flow in the abdominal aorta: a predictor of renal impairment deterioration in patients with renal artery stenosis?. Nephrol Dial Transplant. 2004;19(7):1786-1791. [pmid: 15161949].
41 Uzu T, Takeji M, Yamada N, et al. Prevalence and outcome of renal artery stenosis in atherosclerotic patients with renal dysfunction. Hypertens Res. 2002;25(4):537-542. [pmid: 12358138].
42 Iglesias JI, Hamburger RJ, Feldman L, Kaufman JS. The natural history of incidental renal artery stenosis in patients with aortoiliac vascular disease. Am J Med. 2000;109(8):642-647. [pmid: 11099684].
43 Cheung CM, Wright JR, Shurrab AE, et al. Epidemiology of renal dysfunction and patient outcome in atherosclerotic renal artery occlusion. J Am Soc Nephrol. 2002;13(1):149-157. [pmid: 11752032].
44 Gross CM, Kramer J, Weingartner O, et al. Determination of renal arterial stenosis severity: comparison of pressure gradient and vessel diameter. Radiology. 2001;220(3):751-756. [pmid: 11526278].
45 Spinosa DJ, Matsumoto AH, Angle JF, et al. Safety of CO(2)- and gadodiamide-enhanced angiography for the evaluation and percutaneous treatment of renal artery stenosis in patients with chronic renal insufficiency. AJR Am J Roentgenol. 2001;176(5):1305-1311. [pmid: 11312200].
46 Dorros G, Jaff M, Mathiak L, He T, Multicenter RP. Multicenter Palmaz stent renal artery stenosis revascularization registry report: four-year follow-up of 1,058 successful patients. Catheter Cardiovasc Interv. 2002;55(2):182-188. [pmid: 11835644].
47 Henry M, Henry I, Klonaris C, et al. Renal angioplasty and stenting under protection: the way for the future?. Catheter Cardiovasc Interv. 2003;60(3):299-312. [pmid: 14571477].
48 Rocha-Singh K, Jaff MR, Rosenfield K. Evaluation of the safety and effectiveness of renal artery stenting after unsuccessful balloon angioplasty: the ASPIRE-2 study. J Am Coll Cardiol. 2005;2005(5):776-783.
49 Zeller T, Frank U, Muller C, et al. Stent-supported angioplasty of severe atherosclerotic renal artery stenosis preserves renal function and improves blood pressure control: long-term results from a prospective registry of 456 lesions. J Endovasc Ther. 2004;11(2):95-106. [pmid: 15056029].
50 Bucek RA, Puchner S, Reiter M, et al. Long-term follow-up after renal artery stenting. Wien Klin Wochenschr. 2003;115(21–22):788-792. [pmid: 14743583].
51 Gill KS, Fowler RC. Atherosclerotic renal arterial stenosis: clinical outcomes of stent placement for hypertension and renal failure. Radiology. 2003;226(3):821-826. [pmid: 12601202].
52 Gill-Leertouwer TC, Gussenhoven EJ, Bosch JL, et al. Predictors for clinical success at one year following renal artery stent placement. J Endovasc Ther. 2002;9(4):495-502. [pmid: 12223011].
53 Dangas G, Laird JR Jr, Mehran R, et al. Intravascular ultrasound-guided renal artery stenting. J Endovasc Ther. 2001;8(3):238-247. [pmid: 11491257].
54 Lederman RJ, Mendelsohn FO, Santos R, et al. Primary renal artery stenting: characteristics and outcomes after 363 procedures. Am Heart J. 2001;142(2):314-323. [pmid: 11479472].
55 Rocha-Singh KJ, Mishkel GJ, Katholi RE, et al. Clinical predictors of improved long-term blood pressure control after successful stenting of hypertensive patients with obstructive renal artery atherosclerosis. Catheter Cardiovasc Interv. 1999;47(2):167-172. [pmid: 10376497].
56 White CJ, Ramee SR, Collins TJ, et al. Renal artery stent placement: utility in lesions difficult to treat with balloon angioplasty. J Am Coll Cardiol. 1997;30(6):1445-1450. [pmid: 9362400].
57 Ramos F, Kotliar C, Alvarez D, et al. Renal function and outcome of PTRA and stenting for atherosclerotic renal artery stenosis. Kidney Int. 2003;63(1):276-282. [pmid: 12472793].
58 Gray BH, Olin JW, Childs MB, Sullivan TM, Bacharach JM. Clinical benefit of renal artery angioplasty with stenting for the control of recurrent and refractory congestive heart failure. Vasc Med. 2002;7(4):275-279. [pmid: 12710843].
59 Iannone LA, Underwood PL, Nath A, et al. Effect of primary balloon expandable renal artery stents on long-term patency, renal function, and blood pressure in hypertensive and renal insufficient patients with renal artery stenosis. Cathet Cardiovasc Diagn. 1996;37(3):243-250. [pmid: 8974797].
60 Gross CM, Kramer J, Waigand J, et al. Ostial renal artery stent placement for atherosclerotic renal artery stenosis in patients with coronary artery disease. Cathet Cardiovasc Diagn. 1998;45(1):1-8. [pmid: 9736342].
61 Tuttle KR, Chouinard RF, Webber JT, et al. Treatment of atherosclerotic ostial renal artery stenosis with the intravascular stent. Am J Kidney Dis. 1998;32(4):611-622. [pmid: 9774123].
62 Harjai K, Khosla S, Shaw D, et al. Effect of gender on outcomes following renal artery stent placement for renovascular hypertension. Cathet Cardiovasc Diagn. 1997;42(4):381-386. [pmid: 9408615].
63 Blum U, Krumme B, Flugel P, et al. Treatment of ostial renal-artery stenoses with vascular endoprostheses after unsuccessful balloon angioplasty. N Engl J Med. 1997;336(7):459-465. [pmid: 9017938].
64 Kennedy DJ, Colyer WR, Brewster PS, et al. Renal insufficiency as a predictor of adverse events and mortality after renal artery stent placement. Am J Kidney Dis. 2003;42(5):926-935. [pmid: 14582036].
65 Rivolta R, Bazzi C, Stradiotti P, Paparella M. Stenting of renal artery stenosis: is it beneficial in chronic renal failure?. J Nephrol. 2005;18(6):749-754. [pmid: 16358234].
66 Harden PN, Macleod MJ, Rodger RS, et al. Effect of renal-artery stenting on progression of renovascular renal failure. Lancet. 1997;349(9059):1133-1136. [pmid: 9113012].
67 Radermacher J, Chavan A, Bleck J, et al. Use of Doppler ultrasonography to predict the outcome of therapy for renal-artery stenosis. N Engl J Med. 2001;344(6):410-417. [pmid: 11172177].
68 Ziakka S, Belli AM, Kong TK, MacGregor GA, Missouris CG. Percutaneous transluminal renal artery angioplasty: who benefits most?. Int J Clin Pract. 2002;56(9):649-654. [pmid: 12469977].
69 Burket MW, Cooper CJ, Kennedy DJ, et al. Renal artery angioplasty and stent placement: predictors of a favorable outcome. Am Heart J. 2000;139(1 Pt 1):64-71. [pmid: 10618564].
70 Zeller T, Frank U, Muller C, et al. Technological advances in the design of catheters and devices used in renal artery interventions: impact on complications. J Endovasc Ther. 2003;10(5):1006-1014. [pmid: 14656167].
71 Zeller T, Frank U, Muller C, et al. Predictors of improved renal function after percutaneous stent-supported angioplasty of severe atherosclerotic ostial renal artery stenosis. Circulation. 2003;108(18):2244-2249. [pmid: 14557357].
72 Zeller T, Muller C, Frank U, et al. Survival after stenting of severe atherosclerotic ostial renal artery stenoses. J Endovasc Ther. 2003;10(3):539-545. [pmid: 12932166].
73 Zeller T, Muller C, Frank U, et al. Gold coating and restenosis after primary stenting of ostial renal artery stenosis. Catheter Cardiovasc Interv. 2003;60(1):1-6. [pmid: 12929094].
74 Dorros G, Jaff M, Jain A, Dufek C, Mathiak L. Follow-up of primary Palmaz-Schatz stent placement for atherosclerotic renal artery stenosis. Am J Cardiol. 1995;75(15):1051-1055. [pmid: 7747688].
75 Dorros G, Jaff MR, Mathiak L, et al. Stent revascularization for atherosclerotic renal artery stenosis. 1-year clinical follow-up. Tex Heart Inst J. 1998;25(1):40-43. [pmid: 9566062].
76 Dorros G, Jaff M, Mathiak L, et al. Four-year follow-up of Palmaz-Schatz stent revascularization as treatment for atherosclerotic renal artery stenosis. Circulation. 1998;98(7):642-647. [pmid: 9715856].
77 Dorros G, Jaff M, Mathiak L, et al. Renal function and survival after renal artery stent revascularization may be influenced by embolic debris. J Invasive Cardiol. 2004;16(4):189-195. [pmid: 15152144].
78 Gill-Leertouwer TC, Gussenhoven EJ, Deinum J, van Dijk LC, Pattynama PM. Shrinkage of the distal renal artery 1 year after stent placement as evidenced with serial intravascular ultrasound. Br J Radiol. 2002;75(899):879-883. [pmid: 12466252].
79 van de Ven PJ, Kaatee R, Beutler JJ, et al. Arterial stenting and balloon angioplasty in ostial atherosclerotic renovascular disease: a randomised trial. Lancet. 1999;353(9149):282-286. [pmid: 9929021].
80 Baumgartner I, von Aesch K, Do DD, et al. Stent placement in ostial and nonostial atherosclerotic renal arterial stenoses: a prospective follow-up study. Radiology. 2000;216(2):498-505. [pmid: 10924577].
81 Alhadad A, Ahle M, Ivancev K, Gottsater A, Lindblad B. Percutaneous transluminal renal angioplasty (PTRA) and surgical revascularisation in renovascular disease--a retrospective comparison of results, complications, and mortality. Eur J Vasc Endovasc Surg. 2004;27(2):151-156. [pmid: 14718896].
82 Galaria II, Surowiec SM, Rhodes JM, et al. Percutaneous and open renal revascularizations have equivalent long-term functional outcomes. Ann Vasc Surg. 2005;19(2):218-228. [pmid: 15735947].
83 Cherr GS, Hansen KJ, Craven TE, et al. Surgical management of atherosclerotic renovascular disease. J Vasc Surg. 2002;35(2):236-245. [pmid: 11854720].
84 Marone LK, Cambria RP. Revascularization for renal function retrieval: which patients will benefit?. Pers Vasc Surg Endovasc Ther. 2004;16(4):249-260.
85 Deitch JS, Hansen KJ, Craven TE, et al. Renal artery repair in African-Americans. J Vasc Surg. 1997;26(3):465-472. [pmid: 9308592].
86 Hansen KJ, Cherr GS, Craven TE, et al. Management of ischemic nephropathy: dialysis-free survival after surgical repair. J Vasc Surg. 2000;32(3):472-481. [pmid: 10957653].
87 Hansen KJ, Cherr GS, Dean RH. Dialysis-free survival after surgical repair of ischemic nephropathy. Cardiovasc Surg. 2002;10(4):400-404. [pmid: 12359416].
88 Hansen KJ, Wilson DB, Edwards MS. Surgical revascularization of atherosclerotic renovascular disease: State of the art. Pers Vasc Surg Endovasc Ther. 2004;16(4):281-298.
89 Diamond GA. Limited assurances. Am J Cardiol. 1989;63(1):99-100. [pmid: 2909164].