# List of Abbreviations/Acronyms

Δ: change
ACE: angiotensin converting enzyme
AHRQ: Agency for Healthcare Research and Quality
Appl: applicability rating
ARAS: atherosclerotic renal artery stenosis
ARB: angiotensin-receptor blocker
BP: blood pressure
CABG: coronary artery bypass graft
CAD: coronary artery disease
CHF: congestive heart failure
CI: (95 percent) confidence interval
CKD: chronic kidney disease
CNS: central nervous system
CORAL: Cardiovascular Outcomes in Renal Atherosclerotic Lesions trial
CTA: computed tomographic angiography
CVA: cerebrovascular accident (stroke)
CVD: cardiovascular disease
d: days
DBP: diastolic blood pressure
EPC: Evidence-based Practice Center
GFR: glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m^2^)
GI: gastrointestinal
HDL: high density lipoprotein
HR: hazard ratio
HTN: hypertension
JNC-5: 5th Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure
Imp: improved
KQ: key question
LDL: low density lipoprotein
MAP: mean arterial pressure
MI: myocardial infarction
mo: month(s)
Mod: moderate
MRA: magnetic resonance angiography
N: number evaluated
N/A: not applicable
nd: no data
NIH: National Institutes of Health
NS: nonsignificant
OR: odds ratio
Prosp: prospective nonrandomized study
PTCA: percutaneous transluminal coronary angioplasty
PTRA: percutaneous renal angioplasty
Qual: quality rating
RAS: renal artery stenosis
RCT: randomized controlled trial
Retro: retrospective study
RR: relative risk (risk ratio)
Rx: prescription(s)
SCr: serum creatinine (mg/dL)
STT: “standard triple therapy” of antihypertensive drugs
TEP: Technical Expert Panel
Tufts-NEMC: Tufts-New England Medical Center
UnΔ: unchanged (or stable)
wk: weeks
yr: year(s