# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

Technical Expert Panel

- Richard Paul Cambria, M.D.
- Professor of Surgery
- Chief, Division of Vascular and Endovascular Surgery
- Harvard Medical School
- Boston, Massachusetts

- Scott J. Gilbert, M.D.
- Assistant Professor of Medicine
- Tufts University School of Medicine
- Director, Kidney and Blood Pressure Center
- Tufts-New England Medical Center
- Boston, Massachusetts

- John H. Rundback, M.D.
- Associate Professor of Clinical Radiology
- College of Physicians and Surgeons of Columbia University
- New York, New York

- Stephen C. Textor, M.D.
- Professor of Medicine
- Division of Nephrology
- Department of Medicine
- Mayo Clinic
- Rochester, Minnesota

- Katherine R. Tuttle, M.D.
- Director of Research
- The Heart Institute of Spokane
- Spokane, Washington

AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Elise Berliner, Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD