# Results

The MEDLINE® search yielded 2,163 citations. Members of the Technical Expert Panel and other domain experts added an additional 28 articles for consideration. We identified 375 of these as potentially relevant and retrieved them for further evaluation. Of these 303 did not meet eligibility criteria (see Appendix C for a list of rejected articles along with reasons for rejection); thus 72 articles were included in this report. Due to multiple publications arising from the same studies these 72 articles represent 55 unique studies as per Table 1. An additional five studies met criteria only to provide data on adverse events.

Table 1

Summary of reviewed studies

Intervention | No. Studies | No. Subjects | Intervention Years | Quality | | | Applicability
Intervention | No. Studies | No. Subjects | Intervention Years | A | B | C | III | II | I
Angioplasty+Stent vs Medical RCT | 0
Angioplasty±Stent^A^ vs Medical RCT | 2^B^ | 103 | 1992–5 & nd | | 2 | | | 1 | 1
Revascularization vs Medical Comparison^C^ | 8^D^ | 597 | 1981–2003 & nd | | 2 | 6 | 1 | | 7
Medical treatment cohorts | 4 | 83 | nd | | 1 | 3 | | 1 | 3
Natural History cohorts | 8 | 721 | 1970–98 & nd | | 2 | 5 | | 3 | 4
Angioplasty+Stent cohorts | 21 | 3368 | 1989–2002 & nd | | 10 | 11 | 2 | 5 | 14
Angioplasty±Stent^E^ cohorts | 4 | 427 | 1993–1999 | | 3 | 1 | 1 | 2 | 1
Surgical cohorts | 4 | 921 | 1980–2004 | | | 4 | | | 4
Adverse events | 37^F^ | 5378

nd, no data; RCT, randomized controlled trials.

A Angioplasty without stent or combination of angioplasty with stent and angioplasty without stent.

B DRASTIC study15–17 is included under revascularization vs medical since the randomized phase of the trial lasted only 3 months, too short a duration to meet eligibility criteria. Later followup included comparison between combinations of interventions.

C Combination angioplasty and surgery or surgery vs. medical therapy, either randomized or nonrandomized, or angioplasty vs. medical therapy in a nonrandomized study.

D Includes one the nonrandomized arms of one RCT.

E Combination of angioplasty with stent and angioplasty without stent.

F Including 5 studies that did not qualify for other key questions.

## Direct Comparisons of Angioplasty (or Surgery) With Medical Treatment of Atherosclerotic Renal Artery Stenosis (Tables 2-3,, Figures 2-3)

Table 2

Direct comparisons of angioplasty or surgery and medical treatment for renal artery stenosis

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data, and Table 3 for 30-day mortality data.

Author, Year | Intervention | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | | Qual
Author, Year | Intervention | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | CVD (%) | Qual
Study Design | Intervention | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | Worse | CVD (%) | Appl
Angioplasty vs Medical Treatment, RCT
Webster, 1998^18^ SNRASCG | Angioplasty | 190/99 | >50% | 12 | Ostial 46% | | | | | | | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
Webster, 1998^18^ SNRASCG | No stent | [2.1] | >50% | (12) | Ostial 46% | | BP Δ = −34/−11 | | | | SCr Δ = +0.11 “Renal failure”:^A^ 8% | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (bilateral disease, see other entries) | Medicine | 190/101 | 100% | 16 | nd | (3–54 mo) | | | | | | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (bilateral disease, see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.7] | 100% | (16) | nd | (3–54 mo) | BP Δ = −8/−1 P<0.05 (net) Total Rx Δ = NS(net) | | | | SCr Δ = +0.05 NS (net) “Renal failure”:^A^ 7% | | | Angioplasty:^A^ CHF 9% CVA 4% MI 4% | B
RCT (unilateral disease, see other entries) | Angioplasty | 189/105 | >50% | 13 | Ostial 52% | | | | | | | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | No stent | [1.6] | >50% | (13) | Ostial 52% | | BP Δ = −2/−2 | | | | SCr Δ = +0.09 | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | Medicine | 182/99 | 0% | 14 | nd | (3–54 mo) | | | | | | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
RCT (unilateral disease, see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.9] | 0% | (14) | nd | (3–54 mo) | BP Δ = −10/−2 NS (net) Total Rx Δ = NS(net) | | | | SCr Δ = 0 NS (net) | | | Medical:^A^ CHF 13% CVA 13% MI (unclear) | Mod
Plouin, 1998^19^ EMMA | Angioplasty | 165/98 | >60% | 23 | Ostial 39% | 6 mo | | | | | | | 0/23 | | B
Plouin, 1998^19^ EMMA | +/−stent^C^ | 73 | >60% | (23) | Ostial 39% | 6 mo | BP Δ = −14/−8 Total Rx Final = 1.0 | | | | CrCl Δ = +4 | | | | B
RCT | Medicine^D^ | 165/96 | 0% | 25 | 1992–1995 | | | | | | | | 1/19^E^ | | Low
RCT | Multiple regimens^F^ | 73 | 0% | (25) | 1992–1995 | | BP Δ = −7/−1 p=NS/0.04 (net) Total Rx Final = 1.8 P=0.009(net) | | | | CrCl Δ = 0 NS (net) | | | | Low
Angioplasty vs Medical Treatment or Delayed Angioplasty, RCT
van Jaarsveld, 2000^15–17^ DRASTIC | Angioplasty | 179/104 | 76% | 56 | nd | 1 yr | | | | | | | 4% | | B
van Jaarsveld, 2000^15–17^ DRASTIC | No stent^G^ | 67 | 23% | (56) | nd | 1 yr | BP Δ = −19/−12 Total Rx Δ = −0.8 | | | | CrCl Δ = +3 | | | | B
RCT | Medicine^H^ (n=28) | 180/103 60 | 72% 22% | 50 (50) | 1993–1998 | | | | | | | | 12% | | High
RCT | Multiple regimens I Delayed angioplasty (n=22) | 180/103 60 | 72% 22% | 50 (50) | 1993–1998 | | BP Δ = −17/−7 NS (net) Total Rx Δ = −01 P=0.10(net) | | | | CrCl Δ = +2 NS (net) | | | | High
Angioplasty vs Medical Treatment, Nonrandomized, Controlled Trial
Webster, 1998^18^ | Angioplasty | 196/109 | >50% | 28 | Ostial 63% | | | | | | | | | | B
Webster, 1998^18^ | No stent | [1.9] | >50% | (28) | Ostial 63% | | BP Δ= −13/−11 Total Rx Δ = −0.5NS(base) | | | | SCr Δ= +0.15 | | | | B
NRCT (see other entries) | Medicine | 197/103 | nd | 51 | nd | (3–54 mo) | | | | | | | | | Low
NRCT (see other entries) | 2–3 of atenolol, bedrofluazide, CCB^B^ | [1.6] | nd | (51) | nd | (3–54 mo) | BP Δ = −12/−6 NS (net) Total Rx Δ = +0.3 P=0.01(base) | | | | SCr Δ = 0.05 NS (net) | | | | Low
Taylor, 1989^25^ | Angioplasty | 160/96 | >60% | 5 | nd | 6.5 mo | | | nd | | | | | | C
Taylor, 1989^25^ | No stent | nd | >60% | (nd) | nd | 1–21 mo | BP Δ = −23/−6 Total Rx Δ = −1 | | | | SCrΔ = −0.5 (including 7 receiving surgery) | | | | C
Prosp | No revascularization | 174/100 | nd | 15 | nd | 13 mo | | | 20% | | | | | | Low
Prosp | nd (0–3 drugs) | nd | nd | (nd) | nd | 7–20 mo | BP Δ = −24/−20 Total Rx Δ = 0 | | | | SCr Δ = +1.0 P=0.08 (base); P<0.01 (net) | | | | Low
Englund, 1991^24^ | Angioplasty | 165/96 | nd | 21 | nd | 17 mo | 0 | | | | | | | | C
Englund, 1991^24^ | No stent | [3.9] | nd | (?19–21) | nd | | BP Δ = −9/−5 Total Rx Δ = −1 | | | | SCr Δ = +1.05 | | | | C
Retro | Medicine | 185/101 | nd | 17 | 1981–1988 | 16 mo | 0 | | | | | | | | Low
Retro | nd | [3.8] | nd | (17) | 1981–1988 | | BPΔ = −24/−12 NS (net) Total Rx Δ = 0 NS(net) | | | | SCr Δ = 0.+69 NS (net) | | | | Low
Pizzolo, 2004^20,J^ | Angioplasty | 168/95 | ~88% | 63 | nd | 28 mo | 0 | 57% | 43% | | 82% | | 18% | | C
Pizzolo, 2004^20,J^ | +/−stent^K^ | [1.5] | 30% | (63) | nd | 28 mo | | | | | | | | | C
Retro | Medicine | 159/91 | ~79% | 37 | 1996–2002 | 1–60 mo | 0 | 29% | 71% | | 52% | | 48% | | Low
Retro | Multiple regimens^L^ | [1.4] | 27% | (37) | 1996–2002 | 1–60 mo | P<0.05 | | | | | | | | Low
Angioplasty or Surgery vs Medical Treatment, Nonrandomized, Controlled Trial
Pillay, 2002^21^ | Procedure | nd | >50% | 12 | nd | 2.5 yr | | | | | | | | | C
Pillay, 2002^21^ | Various^M^ | nd | >50% | (nd) | nd | 2.5 yr | DBP Δ = −15 Total Rx Δ = +0.03 | | | | SCr Δ = +0.6 P=0.01 (base) Dialysis: 1/12 | | | | C
Prosp | Medicine | | 100% | 21 | 1994–1998 | >2 yr | | | | | | | | | Low
Prosp | nd | | 100% | (nd) | 1994–1998 | >2 yr | DBP Δ = −6 NS (net) Total Rx Δ = +0.13 NS(net) | | | | SCr Δ = 0 NS (base) Dialysis 0/12 | | | | Low
Johansson, 1999^23^ | Procedure | 179/91 | ≥ 50% | 105 | nd | 7.1 yr | 53% (1 yr) | | | | | | | | C
Johansson, 1999^23^ | Various^N^ | 179/91 | ≥ 50% | (~91) | nd | 7.1 yr | | | | | | | | | C
Prosp | Medicine | 61 | nd | 64 | 1983–1984 & 1988–1994 | | nd | | | | | | | | Low
Prosp | nd | 61 | nd | (~56) | 1983–1984 & 1988–1994 | | | | | | | | | | Low
Surgery vs Medical Treatment, RCT
Uzzo, 2002^22^ | Surgery | nd | ≥ 75% | 25 | nd | 6.2 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | Stop point:^O^68% | C
Uzzo, 2002^22^ | Multiple | nd | ≥ 75% | (25) | nd | 6.2 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | Stop point:^O^68% | C
RCT | Medicine | nd | nd | 27 | nd | up to 7 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | 67% | Low
RCT | nd | nd | nd | (27) | nd | up to 7 yr | No difference in “blood pressure control” (NS) | | | | No difference in dialysis-free survival or change in GFR (NS) | | | NS^P^ | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CHF, congestive heart failure; CKD, chronic kidney disease; CVA, cerebrovascular event (stroke); CVD, cardiovascular disease; DBP, diastolic blood pressure; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m2); HTN, hypertension; Imp, improved; MI, myocardial infarction; mo, months; nd, no data; NS, nonsignificant; Qual, quality rating; RAS, renal artery stenosis; Rx, prescriptions; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); yr, years.

A Combined unilateral and bilateral RAS.

B Or, frusemide, methyldopa, or prazosin. Angiotensin converting enzyme inhibitors were not allowed.

C 21 angioplasty alone, 2 angioplasty with stent.

D Intention to treat. 7 of 26 patients randomized to medical therapy received angioplasty within 6 months.

E ≥ 50% increase in plasma creatinine.

F Goal diastolic blood pressure (DBP)<95 mm Hg, using, if necessary, atenolol 50 mg, furosemide 40 mg, and/or enalapril 10 mg.

G Protocol called for no stent, but stents were placed in 2 patients.

H Intention to treat. 22 of 50 patients randomized to medical therapy at 3 months received angioplasty because of persistent hypertension or deterioration of kidney function.

I Randomized to amlodipine 10 mg (+ atenolol 50 mg if age >40 yr) or enalapril 20 mg (+ hydrochlorothiazide 25 mg if age >40 yr), or if could not tolerate either regimen, atenolol 100 mg (+ hydrochlorothiazide 25 mg if age >40 yr).

J Entry criteria for those receiving angioplasty and those receiving medical therapy were markedly different. Those receiving angioplasty had primary evaluation for resistant hypertension or unexplained azotemia. Those receiving conservative therapy had angiographic evaluation for other causes, primarily lower extremity arteriopathy. Endovascular therapy not considered for this latter group.

K 21 angioplasty alone; 42 angioplasty with stent.

L Goal BP≤140/90. Most frequent used classes of drugs were ACE inhibitors (62%), diuretics (62%), calcium antagonists (49%), and beta-blockers (30%).

M Among 12 patients, “9 angioplasties (1 failure) and 1 bilateral stent. 4 kidneys had… surgery.”

N 88 angioplasty, 17 reconstructive surgery or nephrectomy.

O DBP>100 on treatment, or kidney function worsening (by GFR, SCr, or dialysis), or atherosclerotic cardiovascular event, or death.

P By Cox proportional hazard survival analysis.

Table 3

Adverse events associated with medical and angioplasty treatments of renal artery stenosis in direct comparison studies

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Pizzolo 2004^20^ | 122 (122) | Angioplasty (+/− stent) vs Medical (multiple regimens) | Partial kidney infarction 3% (Angioplasty) Periprocedure acute worsening kidney insufficiency 3% (Angioplasty) | Periprocedure MI 1.6% (Angioplasty) | Cholesterol embolism 1.6% (Angioplasty) | | | 3 of the 4 adverse events occurred in the same person. No data on adverse events in medicine arm
Webster1998^18^ | 55 (55) | Angioplasty (no stent) vs. Medical (atenolol, bedrofluazide, and/or calcium antagonist, or others) | | In hospital stroke 5% (Angioplasty) Symptomatic hypotension 2% (Angioplasty) | No dissections, perforation, or renal artery thrombosis | Bleeding at arterial site 20% (Angioplasty) | No deaths | Pain requiring narcotic analgesicn 10% (Angioplasty) No data on adverse events in medicine arm
Plouin1998^19^ | 49 (49) | Angioplasty (+/− stent) vs. Medical (multiple regimens) | Renal artery dissection 4% (Angioplasty) 0% (Medical) | | No occlusions | Hematoma at puncture site 22% (Angioplasty) 4% (Medical)
Englund1991^24^ | 38 (36) | Angioplasty (no stent) vs. Medical (nd) | Rupture of dilated renal artery & nephrectomy 3% (Angioplasty) | | | | 3%(Angioplasty) 5% (Medical)
Van Jaarsveld 2000^15–17^ | 106 (106) | Angioplasty (no stent) vs. Medical (multiple regimens) or delayed angioplasty | | Periprocedural angina 0% (Angioplasty) 2% (Medical / Delayed angioplasty) Periprocedural MI 0% (Angioplasty) 2% (Medical / Delayed angioplasty) | Occlusion of affected artery 0% (Angioplasty) 16% (Medical / Delayed angioplasty) Rupture of affected artery 0% (All) | Groin hematoma necessitating transfusion or intervention 4% (Angioplasty) 8% (Medical / Delayed angioplasty) | | Embolization of cholesterol crystals 0% (Angioplasty) 14% (Medical / Delayed angioplasty) Symptomatic hypotension at angioplasty 1.8% (Angioplasty) 0% (Medical / Delayed angioplasty)

ARAS, atherosclerotic renal artery stenosis; CVD, cardiovascular disease; d, day; MI, myocardial infarction; N, number evaluated; nd, no data; RAS, renal artery stenosis.

Figure 2

Cumulative mortality after intervention (or start of study period) from 6 months to 6 years, with estimated confidence intervals. See Adverse Events Tables for 30-day mortality data.

Studies reporting mortality rates at multiple time points within the time period of interest have been connected with solid lines. Letters A,18 B,21 C,23 and D20 indicate that these studies reported mortality rates for both medical treatment and an invasive intervention. Conlon 2001^38^ reports different mortality rates for 3 subsets of patients with different degrees of stenosis (see Appendix E Figure for details) so is represented by grey boxes.

See Appendix E Figure for study specific mortality data.

### Key Points for Direct Comparison of Angioplasty (or Surgery) With Medical Treatment of Atherosclerotic Renal Artery Stenosis

- Two randomized controlled trials directly compared angioplasty (mostly without stent placement) to medical treatment only. A third randomized trial compared angioplasty (without stent placement) at the start of the trial (immediate) to a combination of medical treatment alone (56 percent of subjects) and 3 months of medical treatment alone for 3 months followed by angioplasty (delayed, 44 percent of subjects). All trials used a variety of antihypertensive agents. These trials reported outcomes principally at 6 or 12 months; though one followed patients for up to 4.5 years. The studies had methodological flaws making them susceptible to some bias, but not sufficient to invalidate the results (Grade B).
- The randomized trials ranged in applicability to the general population with atherosclerotic RAS (ARAS) from low to high. Two of the studies were conducted in the mid-1990s; the third did not report when enrollment occurred, but it was probably about the same time. Two trials included subjects with at least 50 percent stenosis, one set a minimum of 60 percent stenosis. One trial restricted eligibility to those with unilateral disease, one ran parallel trials of patients with unilateral or bilateral disease, and the third included approximately one-quarter patients with bilateral disease. In the two trials that reported location of stenosis, approximately 40 to 50 percent had ostial disease, as defined by the study authors. On average, all trials included patients with stage 2 chronic kidney disease (glomerular filtration rate 60–89 mL/min). Mean blood pressure in two trials was approximately 180–190/100 mm Hg; the trial restricted to patients with unilateral disease had a lower mean blood pressure of approximately 165/97 mm Hg.
- All trials found clinically small, statistically nonsignificant differences in kidney function; although the trial comparing immediate to delayed angioplasty or medical treatment alone found that substantially fewer patients with immediate angioplasty had worsened kidney function at 1 year (4 vs. 12 percent, statistical significance not reported).
- Differences in blood pressure outcomes varied across the randomized trials. One found substantially greater blood pressure reduction 1 year after angioplasty than with medical treatment among patients with bilateral stenosis (−34/−11 vs. −8/−1 mm Hg), but no difference among patients with unilateral disease. In both groups, the total number of antihypertensive drugs required was similar regardless of intervention. The trial that was restricted to patients with unilateral disease found a net 7 mm Hg greater fall in both systolic and diastolic blood pressure 6 months after angioplasty, but only the change in diastolic blood pressure was statistically significant. In addition, 6 months after angioplasty patients required approximately half as many antihypertensive drugs as those with medical treatment alone (1.0 vs. 1.8). The trial of immediate versus delayed or no angioplasty found no difference in either blood pressure or number of drugs at 12 months.
- Only one trial reported cardiovascular outcomes and found no difference at 12 months in the rate of congestive heart failure, stroke, or myocardial infarction in patients who had either angioplasty or medical treatment only.
- Seven additional studies (including a separate nonrandomized analysis of patients from one of the randomized trials) provided other, either prospective or retrospective, analyses of either angioplasty (mostly without stent placement) or surgery to a wide range of medical regimens. One trial of surgery versus medical treatment was randomized; the remaining studies were not randomized. Of the nonrandomized studies, four evaluated angioplasty, one of which placed stents in approximately two-thirds of patients, and two combined patients who received either angioplasty or surgery. The medical treatments used were generally poorly or not described. Mean study durations ranged from approximately 6 months to 7 years. All but one of these studies were found to be likely to have significant bias that may invalidate the results (Grade C).
- All additional studies were deemed to be of low applicability due to combinations of difficulties assessing study populations due to incomplete reporting, small sample size, high rates of bilateral disease, time period of investigation, inclusion of some patients with fibromuscular displasia, and inclusion of surgical interventions. Four studies included patients first evaluated or treated primarily in the 1980s or earlier; the remaining three included patients from the 1990s or later. Most studies included patients with at least 50 percent stenosis, though the surgical trial included only patients with at least 75 percent stenosis. One study restricted evaluation to those patients with bilateral disease; most of the rest did not report how many patients had bilateral disease. Location of stenosis (ostial versus nonostial) was generally not reported. Of those studies that reported average kidney function, most appeared to include patients with stage 2 chronic kidney disease; an older retrospective study had a population with substantially more severe kidney disease (mean serum creatinine almost 4 mg/dL). Mean blood pressure across studies ranged from approximately 160/95 to 195/110 mm Hg.
- Four of six studies that reported kidney function outcomes found no differences at various time points regardless of intervention. One early prospective study found a significant difference in change in serum creatinine in followup between 1 and 21 months among patients who had either angioplasty or surgery, or had no revascularization (−0.5 vs. +1.0 mg/dL). Another study reported that a substantially greater percentage of patients who had angioplasty (two-thirds of whom had stent placement) had improved or stable kidney function compared to those who were treated medically (82 vs. 52 percent); although they did not report statistical significance.
- Four of six studies that reported blood pressure outcomes found no significant differences in blood pressure control; although two found substantially greater reduction in blood pressure among those who did not have angioplasty, but were treated medically only (−24/−20 vs. −23/−6 mm Hg and −24/−12 vs. −9/−5 mm Hg). One study found no difference in blood pressure change, but a significant difference in the number of antihypertensive drugs required (angioplasty −0.5 vs. medical +0.3). Another found that significantly more patients had improved blood pressure control after angioplasty (two-thirds with stent placement) than medical treatment (57 vs. 29 percent).
- Only the randomized trial of surgical revascularization versus medical treatment of patients with higher grade stenosis reported any outcomes related to cardiovascular disease. They found no difference up to 7 years in the rate of atherosclerotic events, death, worsening kidney function, or resistant diastolic hypertension.
- Three of four studies that reported mortality outcomes found no difference in mortality with either revascularization or medical treatment at a range of time points up to 10 years. However, these studies were not powered to detect differences in mortality. One retrospective study, which used different eligibility criteria for those who had received angioplasty and those treated medically alone found a large and statistically significant higher death rate among patients who did not receive angioplasty.
- No study evaluated quality of life.
- No study reported adverse events due to medical treatment, thus no meaningful comparisons between interventions were made.
- Only two studies evaluated whether baseline variables could predict differential outcomes by intervention. The study comparing immediate to delayed or no angioplasty found that of two diagnostic tests, recent hypertension, bilateral stenosis, and severe stenosis (>70 percent), only bilateral disease was found to be associated with better creatinine clearance at 12 months in those patients who had immediate angioplasty, in contrast to those with unilateral disease, where creatinine clearance was statistically similar in the two groups. No variable predicted relative effectiveness of intervention strategy when diastolic blood pressure was the outcome. The randomized trial of surgical versus medical treatment, found that demographic factors did not help to predict which patients would fare better with either intervention.
- A variety of baseline variables were found to be statistically significantly associated with outcomes (regardless of intervention) across studies. These included higher serum creatinine, percent stenosis, presence of bilateral stenosis, history of cardiovascular disease, and age. However, most of these variables were found not to be associated with outcomes in other studies. Baseline captopril test, renogram, blood pressure, arterial norepinephrine, and angiotensin converting enzyme (ACE) genotype were not associated with outcomes in studies that performed these analyses.
- No study reported data related to any coprocedures or differences in procedures being associated with differential outcomes.

Because of the sparseness of data regarding direct comparisons of revascularization to medical therapy alone, all comparative studies with at least 10 patients, whether prospective or retrospective, were included. For studies that compared medical treatment to angioplasty, we included studies regardless of enrollment date. For studies of either natural history or surgery, that were of lessened applicability due to the interventions used, only studies that included patients whose interventions occurred in 1993 or later were eligible. Comparisons between different revascularization methods or different medical treatments were not included in this section.

Three randomized controlled trials (RCTs, published in five articles) involving a total of 208 patients with ARAS (analyzed, in their randomized arms) compared angioplasty to medical treatments.15–19 Notably, the small sample sizes of the trials suggest that they are likely to be underpowered for the clinical outcomes including mortality, cardiovascular and kidney events. All patients had ARAS. Almost all patients receiving angioplasty did not have stent placement. Medical therapies varied both between and within studies. One study reported results at 6 months, one at 1 year, and one at a variety of time points including 1 year and “most recent” up to 54 months. All three studies had some methodological flaws resulting in a B quality rating. One study each was rated to be of high, moderate, and low applicability.

Six additional studies,20–25 and a nonrandomized third arm from one of the RCTs,18 reported comparisons of either angioplasty or surgery and various medical treatments in a total of 491 patients with RAS; it is unclear how many of these patients had ARAS. One study (Uzzo 2002) was a randomized trial comparing surgery to medical treatment;22 the remaining were nonrandomized comparisons of angioplasty or either angioplasty or surgery to medical treatment. Three studies evaluated angioplasty without stent placement, one evaluated angioplasty with (67 percent) or without (33 percent) stent placement, two evaluated a combined cohort of patients who received either angioplasty (approximately 80 percent) or surgery (approximately 20 percent). The final study evaluated surgical treatment. All compared the invasive intervention with conservative treatment either with or without antihypertensive drugs. Five studies were run prospectively, two retrospectively. Only the nonrandomized arm of the RCT was deemed to be of moderate methodological quality and moderate applicability. The rest were found to have sufficient flaws and of sufficiently limited applicability to be of poor quality and low applicability.

With only two RCTs that directly addressed the comparison of angioplasty with medical treatment for long-term outcomes (≥6 months), and the remainder of the comparative studies being both clinically heterogeneous and mostly nonrandomized, metaanalyses were not performed as these would have added little additional information.

### Methodology Details of Randomized Controlled Trials of Angioplasty Versus Medical Treatment

The three RCTs have previously been reviewed by a Cochrane systematic review.26,27

The SNRASCG study (Webster 1998) was designed to determine if invasive intervention or continued medical therapy resulted in improved blood pressure and preservation of kidney function in hypertensive patients with ARAS.18 In a multicenter study, 55 patients with resistant hypertension with at least 50 percent stenosis were randomized to either angiography without stent placement (n=25) or treatment with, preferentially, atenolol, bendrofluazide and/or a calcium antagonist (n=30). Other eligibility criteria applied. The original intent was to restrict the study to patients with bilateral disease, but those with unilateral disease were subsequently added, but analyzed separately. Their protocol resulted in two randomized groups (bilateral and unilateral disease) and a nonrandomized group of patients with unilateral disease (this latter cohort is reviewed here as a separate, nonrandomized trial). Five of the 25 patients randomized to angioplasty had either a nephrectomy or a surgical bypass at the discretion of the local investigators. Patients were followed at 1 month, 3 months, 6 months after the end of a run-in period or after angioplasty, and then at 6 month intervals thereafter. During the followup period (3 to 54 months) five patients (6 percent) who had been randomly or nonrandomly assigned to medical treatment had an angioplasty. Results are discussed below.

The EMMA study (Plouin 1998) compared angioplasty (mostly without stent placement) to drug treatment, primarily for blood pressure outcomes.19 The multicenter trial randomized 49 patients referred for hypertension and unilateral ARAS of at least 60 percent with a positive lateralization test or stenosis of at least 75 percent without thrombosis, from 1992 to 1995. Patients had resistant hypertension, but a creatinine clearance of at least 50 mL/min. Other eligibility criteria applied. Patients were randomized either to angioplasty alone (n=21) or with stent placement (n=2) or to drug treatment (n=26) by a predefined protocol based on diastolic blood pressure. Seven patients randomized to medical treatment were subsequently excluded from analysis due to a major hypotensive event in one patient and to refractory hypertension for which angioplasty was performed prior to 6 months in six patients. Results, discussed below, were recorded at 6 months.

The largest of the three trials was the DRASTIC trial (van Jaarsveld 2000), which has had three articles published with results.15–17 The goal of the study was to evaluate changes in blood pressure and kidney function after 1 year of treatment in patients who were randomized between immediate angioplasty without stent placement (angioplasty was performed at the start of the trial) and drug therapy (followed by angioplasty if hypertension persisted or kidney function deteriorated). The multicenter study included 106 patients between 1993 and 1998 who had difficult to treat hypertension associated with normal kidney function or a serum creatinine up to 2.26 mg/dL and were found to have ARAS of 50 percent or more by arterial digital subtraction angiography. Other eligibility criteria applied. Patients were randomized to receive either immediate angioplasty (n=56) or to drug therapy (n=50, either amlodipine with atenolol, enalapril with hydrochlorothiazide, or other drug regimens if patients could not tolerate the drugs). Importantly, the primary question addressed involved immediate versus delayed angioplasty, since if after 3 months of medical treatment patients were offered angioplasty if resistant hypertension or kidney deterioration continued. Likewise, a second treatment, including surgical revascularization, was considered after 3 months in patients who received immediate angioplasty. Results data were reported at both 3 and 12 months by intention to treat analysis. By 12 months, 22 of the 50 patients randomized to drug treatment had received angioplasty; 28 remained on antihypertensive treatment alone. Because the randomized portion of the study ended after 3 months, prior to the agreed upon minimum duration of interest for this review (6 months), this trial is categorized with the “other comparative studies.”

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater)

Although mortality was commonly stated to be a primary outcome of the comparative studies, no study was reported to be adequately powered to detect a difference between interventions for this outcome.

##### RCTs of Angioplasty vs. Medical Treatment

Only the SNRASCG randomized trial (Webster 1998) reported mortality data.18 Over 0 to 42 months, the survival curves were nearly identical for those randomized to medical therapy or angioplasty.

##### Other Comparative Studies (Angioplasty or Surgery vs. Medical Treatment)

Mortality data were reported by Pizzolo 2004 in a retrospective analysis of angioplasty with or without stent placement vs. medical treatment,20 two prospective studies of either angioplasty or surgery (Pillay 2002 and Johansson 1999), and the RCT of surgery versus medical treatment (Uzzo 2002).21–23 Pillay 2002 found no difference in all-cause death rates after 2 years between 12 patients who received an invasive intervention and 73 who were treated medically. Johansson 1999 also found no difference in mortality by Kaplan-Meier curve analysis up to 14 years after either angioplasty or surgery (n=105) or of medical treatment (n=64). Only Pizzolo 2004 reported a statistically significant difference in mortality by Cox regression analysis, such that after 5 years of followup, 10 percent of those who had received angioplasty (n=63) had died compared to 34 percent of those who were treated conservatively (n=37). However, eligibility criteria were markedly different for the two retrospective cohorts. Patients who were treated conservatively were diagnosed with RAS based on an angiographic evaluation performed for another cause, primarily peripheral vascular disease. Some of these patients were not treated with angioplasty because of cardiac conditions such as symptomatic coronary artery disease. In contrast, patients who received angioplasty had resistant hypertension or unexplained azotemia. Those treated with angioplasty were significantly younger, by 5 years, had significantly higher high density lipoprotein (HDL) cholesterol, by 5 mg/dL, but had higher baseline diastolic blood pressure, by 5 mm Hg. In the RCT of surgery versus medical treatment, Uzzo 2002 reported only that there were no statistically significant differences in survival in the two groups.22

#### Kidney Function

##### RCTs of Angioplasty vs. Medical Treatment

The two RCTs either estimated creatinine clearance either at 6 months or serum creatinine at multiple time points. Both found nonsignificant, clinically small differences in change in kidney function between those who received angioplasty and those who were treated medically.

The SNRASCG study (Webster 1998) reported that among patients who received angioplasty 8 percent had “renal failure” and 8 percent had “death or dialysis” and among those who were treated medically 7 percent had kidney failure and 13 percent had death or dialysis.18

##### Other Comparative Studies (Angioplasty or Surgery vs. Medical Treatment)

The DRASTIC study reported that 4 percent of patients receiving immediate angioplasty and 12 percent of patients receiving either medical treatment or delayed angioplasty experienced a 50 percent or more increase in serum creatinine level;15–17 however, this was reported as a complication only, no statistical analysis was reported, and it is not reported when or in which patients (those with treatment only or those with delayed angioplasty) this occurred.

Among the three nonrandomized studies comparing angioplasty to medical treatment, two found clinically small, statistically nonsignificant differences in effect on serum creatinine (+0.1 and +0.4 mg/dL). (Taylor 1989 included subjects who had surgical interventions and is discussed below.25) In contrast, Pizzolo 2004 in a retrospective analysis of patients who either received angioplasty with or without stent placement, or (currently used) medical therapy, about 2.5 times more patients on medical therapy (48 percent) had kidney function deterioration at a median of 28 months than those who had had angioplasty (18 percent).20 In a logistic regression model, this outcome was predicted by only intervention type (odds ratio [OR] 3.65, 95 percent confidence interval [CI] 1.28–10.5) and age.

Three studies evaluated kidney outcomes comparing patients who had received either angioplasty or surgery to medical treatment. Taylor 1989 was the only study to find an improvement in kidney function, as measured by serum creatinine, in 12 patients who had an invasive intervention, as compared to an increase among 12 patients who were treated medically.25 The net difference (−1.5 mg/dL) was arguably clinically important and was statistically significant. In contrast, Pillay 2002 found a small, though statistically significant increase in serum creatinine from baseline in 12 patients who had angioplasty or surgery for bilateral stenosis compared to no change from baseline in 21 patients treated medically.21 Only one patient with bilateral stenosis, who had an invasive intervention, required dialysis after over 2 years of followup. Uzzo 2002 in the RCT of surgery versus medical treatment reported no difference in either dialysis-free survival or change in glomerular filtration rate.22

#### Blood Pressure Control

##### RCTs of Angioplasty vs. Medical Treatment

The two RCTs had heterogeneous findings in regard to the comparative effect on blood pressure control of angioplasty or medical treatment. In the SNRASCG study,18 among those with unilateral ARAS a larger reduction in blood pressure occurred among patients treated medically (−10/−2 mm Hg) than those treated with angioplasty (−2/−2 mm Hg); although this difference was not significant. Likewise the total number of drugs used did not significantly differ in the two study arms. In contrast, among patients with bilateral disease, there was a large decrease in blood pressure (−34/−11 mm Hg) in those who had angioplasty, which was highly significantly different than the more modest reduction among patients treated medically (−8/−1 mm Hg, P<0.005). Similarly, although to a lesser extent, EMMA found a greater reduction in blood pressure after angioplasty (−14/−8 mm Hg) than with medical treatment (−7/−1 mm Hg, nonsignificant [NS] for systolic blood pressure, P=0.04 for diastolic blood pressure).19 EMMA also found that those treated with angioplasty were on significantly fewer antihypertensive drugs to control their blood pressure (1.0) than those treated only medically (1.8, P=0.009).

Of note, the Cochrane review performed metaanalysis on different blood pressure results than reviewed here because it used the 3 month data for the DRASTIC study, prior to any crossover of patients from medical treatment to angioplasty.26,27

##### Other Comparative Studies (Angioplasty or Surgery vs. Medical Treatment)

The DRASTIC study, comparing early angioplasty versus either medical treatment or later angioplasty found a clinically large decrease in both systolic and diastolic blood pressures in both study arms (−19/−11 and −17/−7 mm Hg), but no statistically significant difference between the study arms.15–17 Although a greater mean reduction in the number of antihypertensive drugs was found among patients who had early angioplasty, this difference was not statistically significant. Six other comparative studies reported on blood pressure effects. The four that reported changes in blood pressure all found no significant difference between types of intervention. Englund 1991 actually found a larger fall in blood pressure among patients treated medically, though these patients had a substantially higher baseline mean blood pressure.24 The three studies that reported on mean number of antihypertensive drugs all found a larger decrease among patients treated with an invasive intervention than medicine alone, but only Webster 1998 (SNRASCG)18 reported a statistically significant difference (in contrast with the randomized comparisons in the same trial). In addition, one study reported only no difference in blood pressure control.22 However, Pizzolo 2004 in a retrospective analysis of patients who had received angioplasty with or without stent placement or (currently used) medical therapy found that almost twice as many patients treated with angioplasty (57 percent) had improvement in their blood pressure control by standardized criteria than those treated medically alone (29 percent, P<0.05).20

#### Cardiovascular Outcomes

##### RCTs of Angioplasty vs. Medical Treatment

Only Webster 1998 (SNRASCG) reported any cardiovascular outcomes.18 The study combined data from the randomized unilateral and bilateral ARAS arms. Event rates for heart failure, stroke, and myocardial infarction were similar in the two groups. Cox regression that included kidney failure and death or dialysis found no difference after adjustment.

##### Other Comparative Studies (Angioplasty or Surgery vs. Medical Treatment)

The only outcome that was mostly cardiovascular that was reported was a combined stop point of resistant hypertension (diastolic blood pressure > 100 mm Hg on treatment), kidney function worsening, atherosclerotic cardiovascular event, or death. Uzzo 2002 in the RCT of surgical versus medical treatment found no difference.22 This combined outcome was reached in two-thirds of patients at a mean of 6.2 years, regardless of intervention.

#### Adverse Events (Including 30-Day Mortality)

None of the studies reported data to allow a comparison of adverse event or other complication rates between patients receiving angioplasty and those receiving only medical treatment. In general, complication rates related to angioplasty (or angiography) alone were reported. Therefore, these data have been added to the adverse event section below on angioplasty cohort studies.

Only Englund 1991, in a retrospective study of 38 patients from the 1980s, clearly reported 30-day mortality.24 Similar 30-day mortality rates were found in both the angioplasty (3 percent) and medical treatment (5 percent).

### Key Question 2

#### Predictors of Outcomes

Six of the nine studies comparing interventions reported analyses of baseline variables as predictors of outcomes or related subgroup analyses.

##### Baseline Variables as Predictors of Outcomes

###### Baseline kidney function

One retrospective comparison of angioplasty to medical therapy (Pizzolo 2004), one prospective comparison of either angioplasty or surgery to medical therapy (Johansson 1999), and the RCT of surgery to medical treatment (Uzzo 2002) evaluated the association between baseline serum creatinine and outcomes or subgroup analyses.20,22,23

Pizzolo 2004 reported that a baseline serum creatinine greater than 1.5 mg/dL was a borderline predictor of mortality (hazard ratio [HR] = 2.9, 95 percent CI 1-8.3, P=0.05), independent of intervention; however serum creatinine was not a predictor of either blood pressure improvement or of stable or improved kidney function.20 Similarly, Johansson 1999 found that below study median baseline serum creatinine (1.2 mg/dL) was significantly associated with better overall survival through 14 years (P<0.01); however, this univariate analysis did not consider which intervention the patients received.23 In the surgical RCT, in contrast with the finding that intervention type did not predict survival, Uzzo 2002 found that among an unreported number of subjects with azotemia (defined as serum creatinine between 2 and 4 mg/dL), those who had surgical procedures were less likely to die than those treated medically (P=0.01).22

###### Baseline severity of renal artery stenosis

Five studies (in seven articles) evaluated the association between either baseline percent stenosis and outcomes or the comparison between those with unilateral and bilateral ARAS.15–18,20,21,23

The association between percent stenosis and outcomes was reported in two angioplasty RCTs and a prospective study of angioplasty or surgery compared to medical treatment. The DRASTIC study (van Jaarsveld 2000) analyzed the effect of baseline percent stenosis in several ways.15,16 Among the patients randomized to receive immediate angioplasty, baseline stenosis of greater than 70 percent was not associated with blood pressure or dose of antihypertensive drugs compared to lower percent stenosis. However, this analysis was not performed for those who received either delayed angioplasty or medical treatment alone. In analysis of all patients, though, when dichotomized at 80 percent stenosis, there was no significant difference in either creatinine clearance or diastolic blood pressure at 12 months, regardless of intervention. Webster 1998 (SNRASCG), in an analysis of only those patients randomized in the bilateral stenosis part of the trial found that those with an undefined designation of “more severe index of stenosis” …“tended to have higher blood pressure during followup.”18 In a prospective study of either angioplasty or surgery and medical treatment, Johansson 1999 found that stenosis of at least 70 percent was of borderline significance in predicting death, though not accounting for intervention type (relative risk [RR] 1.7, 95 percent CI 1.0–2.9).23

The DRASTIC study also found that presence of bilateral stenosis was not associated with differences in change in diastolic blood pressure between those with either immediate angioplasty or medical therapy with possible delayed angioplasty.15,16 However, among patients with bilateral stenosis those who received immediate angioplasty had significantly better changes in creatinine clearance (+10 mL/min) than those with medicine alone or delayed angioplasty (−4 mL/min). In contrast, there was no difference among patients with unilateral stenosis. Pizzolo 2004 in a retrospective study comparing angioplasty to medical treatment found a borderline association between presence of bilateral disease and the odds of improving blood pressure, independent of intervention.20 Those with bilateral disease were more likely to have blood pressure improvement (OR 3.2, 95 percent CI 0.97–11). Johansson 1999 also found a significant difference in survival among those with either unilateral or bilateral disease such that those with bilateral disease had a 60 percent mortality at 10 years and had all died by 13 years, while those with unilateral disease had approximately 35 percent mortality at 10 and 13 years (P<0.01).23 The RR of death with bilateral stenosis was 2.8 (95 percent CI 1.8–4.6). Visual inspection of the survival graph shows a marked separation of survival by 3 years. In contrast, in another prospective comparison of angioplasty or surgery to medical treatment, Pillay 2002 found no difference in overall survival up to 3 years between those with unilateral or bilateral disease.21

###### Clinical test predictors

Two studies evaluated the predictive value of clinical tests prior to intervention.15,17,23 In the DRASTIC study, neither a positive captopril test nor an abnormal renogram (scintigram) predicted either followup diastolic blood pressure or creatinine clearance in patients receiving immediate angioplasty or medical treatment or delayed angioplasty.15,17 Likewise, in those patients receiving immediate angioplasty abnormal renogram did not predict systolic blood pressure or antihypertensive drug dose at followup. In the Johansson 1999 study, neither arterial norepinephrine level nor unilateral renin secretion was associated with survival.23

Two other studies evaluated baseline ambulatory blood pressure as a predictor of outcomes.17,20 Neither the DRASTIC study nor the Pizzolo 2004 study found an association between either “recent hypertension,” diastolic blood pressure, or baseline number of antihypertensive drugs and either death, followup diastolic blood pressure or creatinine clearance.

###### Other predictors

Pizzolo 2004 found a borderline association between a history of coronary artery disease and death due to a cardiovascular cause (HR 4.3, 95 percent CI 0.9–20, P=0.07).20 Johansson 1999 also found significant RRs for death with histories of diabetes (RR 2.4, 95 percent CI 1.3–4.4), congestive heart failure (RR 2.6, 95 percent CI 1.2–5.7), and coronary heart disease (RR 2.3, 95 percent CI 1.3–3.8); borderline significant RR for death with a history of a cerebrovascular lesion (RR 1.9, 95 percent CI 0.99–3.7), but no association with a history of claudication (RR 1.9, 95 percent CI 0.9–4.0).23

Various demographic variables were also analyzed. Webster 1998, in the randomized bilateral disease group, found that older patients tended to have higher blood pressure at followup. Pizzolo 2004 found that age was not associated with death due to cardiovascular disease, when adjusted for intervention, history of coronary artery disease, and elevated baseline serum creatinine.20 But younger age was independently associated with stable or improved kidney function at followup. Johansson 1999 found that women were less likely to die than men after intervention (RR 0.41, 95 percent CI 0.23–0.72), but that smoking did not predict mortality.23 Uzzo 2002 reported that “interacting baseline demographic factors” did not identify significant differences in reaching a severe end point between the medical or surgical groups.22

Pizzolo 2004 also examined ACE I/D polymorphisms and found that the distribution of genes was not associated with mortality.20

##### Baseline Variables as Predictors of Differential Outcomes by Intervention

Only two studies clearly reported on whether any baseline variables might predict whether patients would fare better with either angioplasty (or surgery) or continued medical treatment. The DRASTIC study, though, actually compared immediate versus delayed angioplasty or continued medical treatment. As described above, among five predictors (captopril test, renogram, recent hypertension, bilateral stenosis, and severe stenosis [>70 percent]) most failed to predict differences in intervention on either diastolic blood pressure or creatinine clearance. Only the presence of bilateral stenosis was found to be associated with better creatinine clearance at 12 months in those patients who had immediate angioplasty, in contrast to those with unilateral disease, where creatinine clearance was statistically similar in the two groups. However, no analysis was performed comparing those who received angioplasty to those who remained on medical treatment only.

Uzzo 2002, in the RCT of surgical versus medical treatment, found that demographic factors did not help to predict which patients would fare better with either intervention.22

### Key Question 3

#### Coprocedure Interventions as Predictors of Outcomes

No study reported data related to any coprocedures or differences in procedures being associated with differential outcomes.

## Medical Treatments for Blood Pressure or Lipid Control of Atherosclerotic Renal Artery Stenosis (Tables 4-5,, Figures 2-3)

Table 4

Medical treatments for blood pressure maintenance of atherosclerotic renal artery stenosis

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data, and Table 5 for 30-day mortality data.

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | Intervention | Mean Followup Duration | Results | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Study Years | (Range) | BP Control | Kidney Function | Cardio-vascular Disease | Appl
Hanzel, 2005^28^ | 154/77 | ≥70% | 40 | Aspirin, statin, and antihypertensive therapy A | 21 mo | BP Δ–11/−5 P=0.03/0.01 | SCr Δ+0.1(+7%) P=0.02 | Stroke 1/40 MI 1/40 | B
Prosp | [≤2. 0] | 18% | (40) | nd | (nd) | BP Δ–11/−5 P=0.03/0.01 | GFR Δ −4 (−6%) P=0.03 | Stroke 1/40 MI 1/40 | Mod
Franklin, 1985^29,30^ | 180/106 | >50% | 13 | Triple-drug regimen cross to enalapril5–20 mg | 7.5^D^ mo | BP Δ–50/−29 P≤0.01 | | | C
RCT & Prosp B | [1.3] C | 49%^C^ | (nd) | nd | (nd) | BP Δ–50/−29 P≤0.01 | | | Low
Ogihara, 1991^31^ | 172/103 | nd | 10 | Delapril7.5–120 mg | Mostly 12 wk>1 yr in some | 8/10 BP Δ ≥−20/−10 | | | C
Prosp | nd | nd | (nd) | nd | Mostly 12 wk>1 yr in some | 5/10 BP Δ ≥−30/−15 | | | Low
Tillman, 1984^32^ | 180/104^E^ | nd | 20 | Enalapril10–40 mg | 19 mo | BP Δ −40/−19^D^ P<0.05 | SCr Δ+0.3 P<0.05 | | C
Prosp | [1.3] | 25% | (≤19) | nd | (8–32 mo) | BP Δ −40/−19^D^ P<0.05 | SCr Δ+0.3 P<0.05 | | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; GFR, glomerular filtration rate (mL/min or mL/min/1.73 m2); HTN, hypertension; mo, months; nd, no data; Mod, moderate; Prosp, prospective nonrandomized study; Qual, quality rating; RAS, renal artery stenosis; RCT, randomized controlled trial; SCr, serum creatinine (mg/dL); wk, weeks; yr, year.

A All patients received aspirin 325 mg/day and a statin to achieve LDL cholesterol <100 mg/dl. Antihypertensive therapy was initiated with an ACE inhibitor or ARB, and other agents were added as necessary. Six patients (15%) developed progressive decreases in single-kidney GFR underwent late renal artery stenting. After stenting, patients received ticlopidine 250 mg twice daily or clopidogrel 75 mg/day for more than 30 days.

B Initially an RCT, then an open-label trial during a “maintenance period.”

C Data was based on the total of 39 patients who were randomized to standard triple therapy group. Of these, in 13 patients therapy was switched from the triple-drug regimen to enalapril during the extension period, and the outcomes were based on these 13 patients.

D Median

E Value was estimated from graph.

Table 5

Adverse events associated with the medical treatment of renal artery stenosis

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS(ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Franklin 1985^29,30^ | 75 (57) | Medical (Enalapril vs STT) | | Orthostatic hypotension 11% (enalapril) CNS symptoms 18% (STT) | | | | No leucopenia, dysgeusia, rash, or proteinuria
Takabatake 1987^33^ | 21 | Medical (Captopril) | | Hypotension comparable in bilateral and unilateral stenosis(nd on %)
Tillman 1984^32^ | 20 (≤19) | Medical (Enalapril) | | Symptomatic tachycardia 20% Angina 5%
Jackson 1986^34,35^ | 16 (16) | Medical (Enalapril) | Increased SCr 25% | | | | | No rash, taste disturbance, or neutropenia
Hricik 1983^36^ | 11 (nd) | Medical (Captopril) | Transient kidney insufficiency 100%

ARAS, atherosclerotic renal artery stenosis; CNS, central nervous system; CVD, cardiovascular disease; d, day; GFR, glomerular filtration rate; MI, myocardial infarction; N, number evaluated; nd, no data; RAS, renal artery stenosis; STT, “standard triple therapy”; SCr, serum creatinine.

A All patients received aspirin 325 mg/day and a statin to achieve LDL cholesterol <100 mg/dl. Antihypertensive therapy was initiated with an ACE inhibitor or ARB, and other agents were added as necessary. Six patients (15%) developed progressive decreases in single-kidney GFR underwent late renal artery stenting. After stenting, patients received ticlopidine 250 mg twice daily or clopidogrel 75 mg/day for more than 30 days.

### Key Points for Medical Treatments for Blood Pressure Maintenance of Atherosclerotic Renal Artery Stenosis

- One cohort study evaluated a combination of aggressive medical treatments, including antihypertensives, aspirin and a statin; this study had some methodological flaws (Grade B). An additional three studies evaluated an ACE inhibitor, in addition to timolol and hydralazine. All three studies had methodological flaws making them susceptible to bias (Grade C).
- Patients’ blood pressures significantly decreased; their kidney function worsened over time. All four studies showed that, on average, the various treatment regimens examined were effective for lowering blood pressures in ARAS patients to or near the normal range. Two studies reported that kidney function worsened over time.
- A wide variety of adverse effects were reported for each antihypertensive agent.
- No study analyzed potential predictors of outcomes.

For the evaluation of medical therapies (not directly compared to revascularization) only prospective trials with at least 10 patients were included, regardless of publication date. Retrospective studies and nonspecified medical treatments were considered in the Natural History section, below.

One prospective trial (Hanzel 2005) involving a total of 40 ARAS (with ≥70% stenosis) patients with hypertension and hyperlipidemia (88%) at baseline used an aggressive medical treatment regimen to achieve a low density lipoprotein (LDL) cholesterol level less than 100 mg/dL in combination with antihypertensive therapy.28 All patients received aspirin 325 mg/day and a statin to achieve the blood lipid control. Antihypertensive therapy was initiated with an ACE inhibitor or angiotensin-receptor blocker (ARB), and other agents were added as necessary. Seven (18%) patients had bilateral stenosis and one (2.5%) patient had stenosis of a solitary kidney. Six patients (15%) who developed progressive decreases in glomerular filtration rate (GFR) subsequently underwent angioplasty with stenting. After stent placement, patients received ticlopidine 250 mg twice daily or clopidogrel 75 mg/day for more than 30 days. Patients were followed up for their clinical outcomes every 3 to 6 months for a median of 21 months. This study also included a cohort of 26 patients who, based on their advanced clinical disease were treated with angioplasty with stent. Because the samples of patients receiving medical treatment alone or angioplasty had substantially different severity of ARAS disease, this study was not included as a study directly comparing the interventions. Because of the small number of patients receiving angioplasty with stent, this study also did not qualify for review as an angioplasty cohort study.

Three prospective studies (published in four articles) involving a total of 43 ARAS patients with stage II hypertension at baseline used different medical treatment regimens for lowering patients’ blood pressures.29–32 Franklin 1985 used a triple-drug regimen, which consisted of initial dosages of timolol 10 mg twice daily, hydralazine 50 mg twice daily, and hydrochlorothiazide, 50 mg (or 100 mg if GFR less than 60 mL/min) daily, with increases in doses as necessary.29,30 After treatment at the maximal dosage for 6 weeks, patients crossed-over to enalapril at an initial dosage of 5 mg twice daily, which could be increased to 10 to 20 mg twice daily, along with hydrochlorothiazide. Ogihara 1991 used delapril with an initial dose of 7.5 mg twice daily.31 The dosage was increased to 30, 60, or 120 mg daily if needed. Tillman 1984 employed enalapril 10 to 40 mg, titrated to blood pressure less than 140/90 four hours after dose.32 The number of patients with ARAS were not described in two studies, and was less than the number of evaluated patients in one study. It is difficult to determine the patients’ kidney functions at baseline based on the limited data reported. The duration of followup ranged from 12 weeks (in some and 12 months in others) to 32 months.

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater), Kidney Function, and Blood Pressure Control

The study of aggressive medical treatment for blood lipid control (targeting LDL cholesterol <100 mg/dL) in combination with antihypertensive therapy showed that, on average, patients’ blood pressures significantly decreased from 154/77 to 143/72 mm Hg at follow-up. However, there was a 7% increase in serum creatinine concentration (from mean 1.3 to 1.4 mg/dL), and 6% and 8% decreased in the total kidney and stenotic kidney GFR respectively. Six patients (15%) developed progressive decreases in single-kidney GFR and underwent late renal artery stenting.

All four studies of medical treatments for blood pressure control showed that, on average, various treatment regimens were effective for lowering blood pressures to the normal ranges (or the prespecified blood pressure goals). The three studies that analyzed statistical significance found that the blood pressure reduction was statistically significant compared to baseline. Two studies examined the changes in patients’ kidney function and found similar small, but statistically significant worsening in kidney function over approximately 2 years.28,32 Tillman 1984 also reported an overall mortality rate of 5 percent after 8 to 32 months of followup.32

#### Cardiovascular Outcomes

Among the 40 ARAS patients in the study of aggressive medical treatment including blood lipid control, one patient (2.5%) experienced stroke and one patient (2.5%) experienced myocardial infarction during the follow-up period.

The studies of antihypertensive drugs alone did not report any cardiovascular outcomes.

#### Adverse Events (Including 30-Day Mortality)

Adverse events associated with the use of enalapril included orthostatic hypotension symptoms, muscle cramps, headaches, increased serum creatinine levels, developing or worsening Raynaud’s phenomenon, angina, and symptomatic tachycardia. No rash, taste disturbance, leucopenia, dysgeusia, neutropenia, or proteinuria was reported.

Adverse events associated with the use of timolol and hydralazine included central nervous system symptoms, digestive symptoms, headaches and nausea.

Adverse events associated with the use of captopril included hypotension and transient kidney insufficiency.

### Key Questions 2 & 3

#### Predictors of Outcomes

No analyses were reported that evaluated baseline variables as predictors of outcomes.

## Natural History or Nonspecified Medical Treatments for Atherosclerotic Renal Artery Stenosis (Table 6 , Figures 2-3)

Table 6

Natural history or nonspecified medical treatments of atherosclerotic renal artery stenosis

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | Intervention | Mean Followup Duration | Results | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Study Years | (Range) | BP Control | Kidney Function | Cardiovascular Disease | Appl
Caps, 1998^37^ | 163/84^A^ | ≥60% | 100^B^ | Medical Rx | nd | | Kidney atro 21% C | | B
Prosp | [1.6] A | nd | (100) | 1990–1993 | (2–24 mo) | | Kidney atro 21% C | | Mod
Cheung, 2002^43^ | 167/87 | ≥50% | 26 or 11^D^ | Mostly medical Rx^E^ | 35 mo | | Δ GFR: −4.9/yr (n=11) GFR Δ >20%: 6/11 | | C
Prosp & Retro | 35.5 | 100% | (nd) | nd | (1–82 mo) | | Δ GFR: −4.9/yr (n=11) GFR Δ >20%: 6/11 | | Low
Conlon 2001^38^ | nd | ≥50% | 362 | Various | 3.2 y | | Only mortality data reported | | B
Prosp | [1.2] | 17% | (nd) | nd | (6–90 mo) | | Only mortality data reported | | Low
Fergany, 1994^39^ | 179/102 | nd | 20 | Medical Rx | 43 mo | BP Δ−39/−17 P=0.03 | SCr Δ +0.2 NS | | C
Prosp | [1.2] | 65% | (nd) | 1970–1990 | (4–120 mo) | BP Δ−39/−17 P=0.03 | SCr Δ +0.2 NS | | Low
Houston, 2004^40^ | nd | >60% | 45 | nd | 9 yr | | SCr Δ +0.3^F^ P=0.004 | | C
Prosp | [~1.8]^F^ | nd | (nd) | nd | | | SCr Δ +0.3^F^ P=0.004 | | Mod
Iglesias, 2000^42^ | 143/84 | >20% | 96 or 78^G^ | nd | 55 mo | | Δ SCr: +0.06/yr (n=78) | | C
Retro | [1.2] | 20% | (nd) | nd | (nd) | | Δ SCr: +0.06/yr (n=78) | | Mod
Pillay, 2002^21^ | nd/88^F^ | >50% | 52 or 35^H^ | Medical Rx | 2 yr | DBP Δ −8^F^ P=NS | SCr Δ +0.2^F^ (n=35) P=0.002 Dialysis: 2/52 | | C
Prosp | [1.2]^F^ | 0% | (nd) | 1994–1998 | (2 yr) | DBP Δ −8^F^ P=NS | SCr Δ +0.2^F^ (n=35) P=0.002 Dialysis: 2/52 | | Low
Uzu, 2002^41^ | 170/77 | ≥ 75% | 20 | Medical Rx | nd | | Dialysis: 8/20 | CVD deaths: 8/20 | B
Prosp | [3.2] | 59% | (nd) | 1996–1998 | (3–36 mo) | | Dialysis: 8/20 | CVD deaths: 8/20 | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CVD, cardiovascular disease; DBP, diastolic blood pressure; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m2); mo, months; Mod, moderate; nd, no data; NS, nonsignificant; Qual, quality rating; RAS, renal artery stenosis; Rx, prescription; SCr, serum creatinine (mg/dL); yr, years.

A Data were based on all 204 kidneys, including 43 (21 percent) kidneys with normal baseline arteries at baseline.

B Number of kidneys

C Cumulative incidence of kidney atrophy (a reduction in kidney length >1 cm during followup compared to the length at baseline examination) over a period of 2 year

D Only nondialysis and survived patients with baseline renal functional data were analyzed for followup renal function analyses.

E Very few patients received angioplasty; of which only one received stent.

F Value was estimated from graph.

G Patients who died within 180 days excluded from analyses of annual changes SCr. These patients had better survival rate than the whole cohort.

H Survivors only.

### Key Points for Natural History or Nonspecified Medical Treatments for Atherosclerotic Renal Artery Stenosis

- Eight studies reported outcomes of natural history or nonspecified medical treatments for ARAS. Of these, the four that reported intervention dates, ranged from 1970 to 1998. Almost all patients in these studies received no revascularization interventions and presumably all patients were under standard care by their physician. Populations were heterogeneous across studies. The majority of studies had methodological flaws making them susceptible to bias (Grade C), while three studies were of moderate quality (Grade B).
- Mortality outcomes were reported in five studies. Six-month, 2-, 4-, and 5-year survival rates were 77 percent, 60 to 68 percent, 64 percent, and 38 percent, respectively.
- Kidney function outcomes were reported in six studies. In general patients’ kidney function deteriorated over time, although to different degrees in the different studies.
- Outcomes of blood pressure control were reported in two studies. The results were not comparable due to substantial differences in the ARAS populations examined.
- One study reported eight fatal cardiovascular events in 20 patients with severe stenosis (≥ 75 percent) during 3 to 36 months followup.
- Four studies analyzed various predictors of mortality and/or outcomes of kidney function. Percent stenosis and baseline kidney function were found to be strong predictors of death (or dialysis) in separate studies. Another study found that nonspiral blood flow in the renal arteries predicted kidney function deterioration. Other variables related to cardiovascular disease were also found to predict death. One study found that bilateral versus unilateral disease did not predict progressive kidney disease.
- One study found that patients with bilateral disease had higher cardiovascular mortality rate than with unilateral disease.

For observational studies of natural history or nonspecified medical treatments of ARAS, we included both prospective and retrospective studies with at least 10 patients. At least some of patients in the included studies had to be followed in or after 1993.

Six prospective studies,21,37–41 one retrospective study,42 and one mixed prospective and retrospective study43 involving a total of 721 patients reported outcomes of natural history or nonspecified medical treatments for ARAS. Of these, four studies reported the intervention dates, ranging from 1970 to 1998. Almost all patients in these studies received no revascularization interventions (among five studies reporting on this) and presumably all patients were under standard care by their physician. Populations were heterogeneous across studies. Only one study described the number of patients with ARAS.37 The mean serum creatinine levels ranged from 1.2 to 3.2 mg/dL at baseline, implying at least stage 2 chronic kidney disease (GFR 60–89 mL/min). The percent stenosis ranged from greater than 20 percent to greater than 75 percent; the percentage of bilateral stenosis ranged from 17 to 100 percent. The duration of followup for individual patients ranged from 1 to 120 months. The majority of patients had hypertension although the severity varied.

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater)

Mortality outcomes were reported in five studies. Six-month, 2-, 4-, and 5-year survival rates were 77 percent, 60 to 68 percent, 64 percent, and 38 percent, respectively. Conlon 2001 also analyzed the survival rate by severity of ARAS.38 All 362 patients had coronary artery diseases at enrollment. The 4-year survival in patients with 50 to 75 percent, 75 to 95 percent, and >95 percent ARAS was 70 percent, 68 percent, and 48 percent respectively (P<0.001 for trend).

#### Kidney Function

Kidney function outcomes were reported in seven studies. A variety of outcomes for kidney function were examined. Although different measures of kidney function were measured, data from all studies showed that in general patients’ kidney function deteriorated over time, although to different degrees. Caps 1998 showed that the cumulative incidence of kidney atrophy (defined as a reduction in kidney length greater than 1 cm from baseline) was 21 percent over a 2-year period in 100 patients with ARAS.37 Cheung 2002 showed that the mean annual change in GFR was −4.9 mL/min/year in 11 patients with bilateral stenosis.43 Of these patients, six had GFR fall by more than 20 percent during the followup period. Four studies examined the changes in serum creatinine; all showed that, on average, serum creatinine levels increased over time in a total of 178 ARAS patients. Two studies reported the rate of dialysis in a total of 72 ARAS patients. One study found that two (4 percent) of the 52 patients with significant unilateral stenosis (>50 percent) required dialysis in the 2-year followup, while the other study reported that eight (40 percent) of the 20 patients with severe stenosis (≥75 percent) required dialysis during 3 to 36 months followup.

#### Blood Pressure Control

Blood pressure control was reported in two studies. Pillay 2002 showed that median diastolic blood pressure did not change significantly in 35 unilateral ARAS survivors.21 Fergany 1994 showed that the mean blood pressures decreased 39/17 mm Hg after medical treatment in 20 ARAS patients (65 percent with bilateral stenosis).39

#### Cardiovascular Outcomes

Uzu 2002 reported eight fatal cardiovascular events in 20 patients with severe stenosis (≥75 percent) during 3 to 36 months of followup.41 These fatal cardiovascular events included cerebral hemorrhage (n=2), myocardial infarction (n=4), and cerebral infarction (n=2).

#### Adverse Events (Including 30-Day Mortality)

These studies of natural history did not report adverse events.

### Key Questions 2 & 3

#### Predictors of Outcomes

Two studies examined various predictors (e.g. baseline clinical, laboratory and anatomic characteristics) of mortality using multivariable Cox proportional hazard models.38,43 Conlon 2001 found that the presence of significant ARAS (≥75 percent stenosis), increased age, the severity of coronary artery disease (CAD), the presence of comorbid disease, reduced ejection fraction, symptoms of congestive cardiac failure, and the mode of treatment of CAD were all independently associated with reduced survival in ARAS patients with CAD. Also, as noted above, in univariate analysis, patients with greater percentage stenosis had progressively higher mortality rates. Cheung 2002 reported that the baseline kidney function was the most important prognostic variable, with renal vascular anatomy having no additional, or independent, prognostic impact on combined death and dialysis-need end point. Compared to patients with baseline GFR more than 50 mL/min, the hazard ratio of death or dialysis was 1.4, 4.4, and 29 in patients with baseline GFR 25 to 50 mL/min, 10 to 25 mL/min, and less than 10 mL/min, respectively.

Three other studies evaluated the predictors of outcomes of kidney function by univariate analyses.40–42 Houston 2004 found that patients with nonspiral blood flow (an evaluation of the direction of flow on magnetic resonance angiography) of the kidneys had significant progression in kidney impairment (P=0.007), while patients with spiral blood flow of kidneys did not. Iglesias 2000 reported that bilateral stenoses did not worsen kidney disease prognosis. Uzu 2002 found that the cardiovascular mortality rates were 13 and 18 per 100 patient-years in patients with unilateral ARAS and bilateral ARAS respectively.41 The difference was statistically significant (P=0.01).

## Angioplasty With Stent Placement of Atherosclerotic Renal Artery Stenosis (Tables 7-8,, Figures 2-3)

Table 7

Angioplasty with stent placement for treatment of renal artery stenosis See Figure 2 (page 72) and Appendix E Figure for long-term mortality data, and Table 8 for 30-day mortality data.

| | | | | | Results
Author, Year | Mean BP | Mean % Stenosis | No.x Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | Worse | % Restenosis | Appl
Kennedy, 2003^64,69^ A | 168/82 | >60^B^ | 261 | nd | 21 mo | | | | | | | | 48 | B
Prosp | 51 | 38 | (253) | 1993–2001 | 1–85 | BP Δ = −19/−6 P=0.0001 | | | | CrCl Δ =−2 P <0.05 | | | 17 mo | High
Rocha-Singh, 2005^48^ | 168/82 | >70 | 208 | Ostial 100% | nd | | | | | | | | 17^C^ | B
Prosp | [1.4] | 21 | (208) | 1997–1999 | 9–24 mo | BP Δ = −19/−5 P=0.001 | | | | SCr Δ = +0.10 P<0.04 | | | 9 mo | Mod
Dangas, 2001^53^ D | 170/84 | 74 | 131 | Ostial 75% | 15 mo | | 47 | 40 | 13 | 18 | 61 | 21 | nd | B
Prosp | [1.9] | 17 | (nd) | nd | nd | BP Δ = −15/−10 P<0.001 | | | | | | | nd | Mod
White, 1997^56^ | 173/88 | >50 | 100 | Ostial 81% | 6 mo | | | | | | | | 19^C^ | B
Prosp | [2.4] | 33 | (100) | 1992–1994 | nd | BP Δ = −27/−11 P<0.01 | | | | | | | 6 mo | Mod
Gill, 2003^51^ | 191/98^E^ | >50^F^ | 100^G^ | Ostial 78% | 25 mo | 4 | 79 | 17 | | 31 | 42 | 31 | 66^H^ | B
Prosp | [2.7] I | 26 | (100) | 1993–1999 | 1–66 | BP Δ = −27/−12/ P<0.01 | | | | SCr Δ = −0.6 mg/dL^J^ NS | | | 11 mo | Mod
Blum, 1997^63^ | MAP 133 | >50 | 68 | Ostial 100% | 27 mo | 11 | 42 | 15 | | | | | 12 | B
Prosp | [1.2] | 9 | (68) | 1989–1996 | 3–84 | MAP Δ = −20 P<0.0001 | | | | SCr Δ= 0 NS | | | 3–24 mo | Low
Iannone, 1996^59^ | 160/80 | 67 | 63 | Ostial 78% | 10 mo | 4 | 35 | 54 | 7 | 36 | 46 | 18 | 14^c^ | B
Prosp | [1.8] | 22 | (63) | 1992–1993 | 1–22 | BP Δ = −15/0 P=0.004/NS | | | | SCr Δ = 0.2 NS | | | 11 mo | Mod
Harden, 1997^66^ | 169/95 | >50 | 32 | Ostial 75% | 17 mo | | | | | 34 | 34 | 28 | 12.5 | B
Prosp | nd | 34 | (32) | 1992–1995 | nd | BP Δ = −6/−8 NS/<0.01 | | | | | | | 6 mo | Mod
Zeller, 2004^49,70–73^ | 102 | >70 | 354^K^ | Ostial 95% | 34 mo | | 46 | 43 | 11 | 10 | 39 | 27 | nd | B
Prosp | [1.5] | nd | (340) | 1996–2002 | 2–79 | MAP Δ = −8 P<0.0001 | | | | GFR Δ = +3.0 NS | | | nd | Mod
Gross, 1998^60^ | 163/93 | 75 | 30 | Ostial 100% | 6 mo | | 69 | 31 | | | | | 12.5 | B
Prosp | [1.4] | 23 | (30) | nd | nd | BP Δ =−18/−10 P=0.004/0.007 | | | | | | | 6 mo | Low
Dorros, 2002^46,74–77^ | 168/84 | nd | 1058 | nd | nd | | | | | | | | nd | C
Prosp | [1.7] | 36 | (1058) | 1990–1997 | 1–4 yr | BP Δ = −21/−6 P<0.05 | | | | SCr Δ = −0.4 P<0.05 | | | | Mod
Ledermen, 2001^54^ | 164/84 | 62 | 300 | Ostial: 95% | 16 mo | | 70 | | | 8 | 78 | 14 | 21 | C
Prosp and Retro | [1.5] | 41 | (293) | 1993–1998 | 6–24 | BP Δ = −22/−8 | | | | SCr Δ = +0.11 P=0.05 | | | 17 mo | Mod
Rocha-Singh, 1999^55^ | 110 MAP^L^ | >75 | 150 | Ostial 43% | 13 mo | 6 | 50 | 44 | | 23 | 69 | 8 | 12^C^ | C
Prosp | [1.5]^M^ | 20^N^ | (150) | 1993–1995 | nd | | | | | SCr Δ = +0.04 NS | | | 13 mo | Mod
Tuttle, 1998^61^ | 160/84 | >70 | 129 | Ostial 100% | nd | 55 | | | | 15 | 81 | | 14^C^ | C
Prosp & Retro | 40 | 15 | (129) | 1991–1996 | 6–24 | BP Δ = −8/−4^O^ P<0.05 | | | | CrCl Δ= 0 NS | | | 8 mo | Mod
Ramos, 2003^57^ | 160/91 | >70 | 105 | Ostial 32% | 12.2 mo | 18 | 47 | | | | | | 14 | C
Prosp | 54 | 43 | (105) | nd | 3.3–23 | BP Δ = −15/−8 P<0.0001 | | | | GFR Δ = +8 P=0.007 | | | 12 mo | Mod
Harjai, 1997^62^ | 178/91 | >70 | 66 | Ostial 73% | 19 mo | 66 | | | | | | | 25 | C
Prosp | [1.6] | 27 | (66) | 1992–1995 | nd | BP Δ = −32/−17 nd | | | | | | | 9 mo | High
Henry, 2003^47^ | 169/104 | 85 | 56 | Ostial 100% | 23 mo | 18 | 59 | 23 | | 18 | 82 | 0 | nd | C
Prosp P | [1.3] | 14 | (56) | 1999–2002 | 2–47 | BP Δ = −19/−11 P<0.01 | | | | SCr Δ = −0.1 mg/dL NS | | | nd | Low
Rivolta, 2005^65^ | 161/86 | >70 | 52 | nd | 24 | | | | | 15 | 60 | 25 | 10 | C
Prosp | [2.9] | 37 | (52) | | 9–54 | BP Δ = −18/−7 P<0.01^Q^ | | | | | | | 6 mo | Mod
Gill-Leertouwer, 2002^52,78^ | 177/96^R^ | >50 | 40 | nd | 1 yr | | | | | | | | 14 | C
Prosp | [1.3]^S^ [2.4]^T^ | nd | (40) | 1996–1998 | nd | Clinical success 85% | | | | Clinical success 25% | | | 12 mo | Low
Bucek, 2003^50^ | nd | >80 | 40 | Ostial 100% | 3.3 yr^U^ | | 38 | 43 | | | | 25 | 13–15 | C
Prosp & Retro | nd | nd | (40) | 1997–2002 | 0.8–6.3 | | | | | | | | 40 mo | Low
Gray, 2002^58^ V | 174/85 | >70 | 39 | nd | 21 mo | | 72 | 15 | | 51 | 26 | 23 | 10 | C
Prosp | [3.2] | 46 | (39) | 1991–1997 | 1–61 | | | | | | | | 21 mo | Mod

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure;, CKD, chronic kidney disease; CVD, cardiovascular disease; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m2)); HTN, hypertension; Imp, improved;, mo, months; MAP, mean arterial pressure; Mod, moderate; nd, no data; NS, nonsignificant;, Prosp, prospective nonrandomized study; Qual, quality rating; RAS, renal artery stenosis; Retro, retrospective study; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); yr, years.

A CVD outcomes: myocardial infarction 11%; CHF 20%; stroke 7%.

B Diagnosed by digital caliper technique.

C % restenosis reported according to the arteries evaluated.

D Myocardial infarction 5%.

E Among 48/50 with resistant HTN.

F N=102/126 > 85% stenosis.

G N analyzed at baseline for BP=48 and CKD=65.

H Of the arteries evaluated: Neointimal hyperplasia 61%; stent migration 22%, and true stent restenosis 17%.

I Among 65/75 with CKD at baseline.

J N analyzed = 18.

K Evaluated at follow-up n=113.

L Outcomes evaluated n=127.

M Outcomes evaluated n=132.

N Among those with follow-up (n=127).

O Analyzed at 12 mo (n=41).

P Utilized distal protection device and follow-up data available for maximum numbers at 6 month.

Q Significant only for systolic blood pressure.

R 60% less than 2 yr duration of HTN.

S Baseline value among those with clinical success (n=27).

T Baseline value among those with clinical failure (n=13).

U Median.

V New York Heart Association class Δ=−1.4 P<0.001.

Table 8

Adverse events associated with angioplasty with stent placement treatment of renal artery stenosis See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Dorros 2002^46,74–77^ | 1058 | Angioplasty stent placement | Contrast induced acute kidney failure 13% | | | Retroperitoneal hemorrhage 1 % | Deaths 0.3%
Zeller 2004^49,70–73^ | 340 268 (268) | Angioplasty stent placement | Severe deterioration of kidney function 1.5% Local dissection or perforation 4% | | False aneurysm 1% Access site occlusion 0.3% | Severe access site bleeding 2% | 30 d mortality 0.6% Death after 3 d due to embolic stroke 0.3% | Stent displacement 1%
Lederman 2001^54^ | 300 (293) | Angioplasty stent placement | Guidewire induced dissection of renal artery branch 0.3% | | Intraprocedural thrombosis of the target renal artery 0.3% | | Death from MI 0.3% | Acute/flash pulmonary edema 0.3% Stent migration into aorta 0.3% Aspirin hypersensitivity 0.3%
Kennedy 2003^64,69^ | 261 (253) 127 (127) | Angioplasty stent placement | | | Total occlusion of stented artery 0.8% | Hematuria due to vessel perforation 0.8% | | Access site complications with brachial approach 3% Access site complications with femoral approach 3% Dislodged stent 1.0% Dislodged unexpanded stent 0.8%
Rocha- Singh 2005^48^ | 208 (208) | Angioplasty stent placement | | [underlined: In-hospital] Major hemorrhage 1% Major vascular event 2% [underlined: Out of hospital up to 2 yr] Major hemorrhage 0.5% | [underlined: In-hospital] Major embolic event 1.4% Stent thrombosis 0.5% | | | Access site complications 5%
Rocha- Singh 1999^55^ | 150 (150) | Angioplasty stent placement | Contrast induced nephropathy 5% Kidney parenchymal guidewire perforations 1.3% | | | | Death from tubular necrosis and multiorgan failure 0.7% Death from GI hemorrhage after stent implant while on warfarin 0.7% | Overall major complication rate 3%
Dangas 2001^53^ | 131 (nd) | Angioplasty stent placement | Kidney failure 6% | | Femoral artery pseudoaneurysms 1.5% | | Death 0.8 %
Tuttle 1998^61^ | 129 (129) | Angioplasty stent placement | Contrast induced acute kidney failure 12% | | Atheroembolic disease 0.7% Arterial thrombosis 0.4% | Groin hematoma 7% Perirenal hematoma 0.4% | Death 3% | Stent migration 0.7%
Gill 2003^51^ | 100 (100) | Angioplasty stent placement | Transient SCr rise 1% | | Transient lobar branch renal artery occlusion 2% Femoral artery false aneurysm 2% Femoral artery trauma 2% Non flow limiting intimal dissection 1% | Groin hematoma 6% | Death after lower limb cholesterol embolization 1% Death after thrombosis of aortofemoral prosthetic graft 1% | Migrating stent 1%
White 1997^56^ | 100 (100) | Angioplasty stent placement | Transient contrast nephropathy 2% No perforations | | Femoral artery pseudoaneurysm 1% Brachial artery occlusion 1% Subacute stent thrombosis after 3 d 1% | Groin hematoma 5% | Ischemic cardiac death after 2 d 1%
Blum 1997^63^ | 68 (68) | Angioplasty stent placement | | | | Local hematomas at puncture site 4% | | No major complications
Harjai 1997^62^ | 66 (nd) | Angioplasty stent placement | Temporary rise in SCr 5% | | | Minor bleeding from vascular access site 5%
Iannone 1996^59^ | 63 (61) | Angioplasty stent placement | Acute kidney failure 13% Renal artery perforation 5% | | Psuedoaneurysm at insertion site 1.6% | Minor groin hematoma 10% Bleeding requiring transfusion including peripheral embolus requiring thrombolysis 16% | Death after perirenal bleeding 1.6%
Henry 2003^47^ | 56 (56) | Angioplasty stent placement | | | Arterial spasm at site of protection device 4% | | Death on d 3 from MI 1.8% | No device related complications
Harden 1997^66^ | 32 (32) | Angioplasty stent placement | | | Femoral artery pseudoaneurysm 9% | Hemorrhage 9% | Death from circulatory collapse after stent placement 3%
Gross 1998^60^ | 30 (30) | Angioplasty stent placement | Dissection after predilatation 10% | | No vessel had early or subacute thrombotic occlusion | | | No guidewire perforation detected.

ARAS, atherosclerotic renal artery stenosis; CKD, chronic kidney disease; CVD, cardiovascular disease; d, days; GI, gastrointestinal; MI, myocardial infarction; N, number of subjects; nd, no data; PTRA, percutaneous renal angioplasty; RAS, renal artery stenosis; SCr, serum creatinine.

### Key Points for Angioplasty With Stent Placement for Atherosclerotic Renal Artery Stenosis

- This review evaluated 21 studies that placed stents in all patients that included a total of 3368 patients for clinical outcomes. Only prospective studies that evaluated at least 30 patients, at least some of whom were treated since 1993, were included. Almost all studies evaluated outcomes using before and after designs of interventions without controls (cohort study designs), and thus have important sources of biases. Approximately half the studies were rated to be moderate quality (Grade B), half poor quality (Grade C).
- Overall, uncontrolled hypertension was the most common indication for a percutaneous intervention. At baseline, patients frequently had diffuse atherosclerotic vascular diseases. The studies followed patients for 1 to 2 years after intervention. Almost two-thirds of the studies were of moderate applicability to the populations of interest; only two studies were of high applicability.
- The majority of the patients had cured or improved blood pressure rates at followup compared to baseline. However the improved kidney outcomes and mortality rates varied across the studies and handful of studies reported cardiovascular disease outcomes. The most frequent cause of mortality was related to cardiovascular disease.
- Restenosis was evaluated between 3 to 40 months after percutaneous interventions and the rates of restenosis ranged from 10 to 21 percent. One study noted a statistically significant higher rate of restenosis among those who had undergone stent placement for ostial lesions compared to those with nonostial lesions
- Adverse events following angioplasty included 30-day mortality that ranged from <1 to 3 percent and transient decline in kidney function that ranged from 1 to 13 percent.
- A decreased baseline kidney function predicted mortality outcome. However, the studies differed in their description of decreased baseline kidney function. Of note, the studies also varied if decreased kidney function at baseline predicted deterioration or improvement in kidney function following intervention. Improved kidney function was also observed with baseline resistance index of more than 80 percent.
- Baseline congestive heart failure (CHF) and the extent of CAD predicted an increased risk of cardiovascular- and kidney-related mortality. Survival after stent placement was adversely influenced by the presence of baseline bilateral ARAS with and without baseline chronic kidney disease.
- Only one study analyzed the effect of periprocedural interventions – simultaneous bilateral stent placement on outcomes.

Because of the relatively large number of studies on angioplasty, it was agreed to restrict the review to the most applicable studies that are less likely to have substantial bias. Thus only prospective studies of angioplasty with stent placement, with at least 30 patients who were treated and analyzed after 1993 are included. Studies in which more than 20 percent of the subjects had a previous revascularization procedure were excluded. Studies that evaluated both angioplasty with stent placement and angioplasty are reviewed separately, below. Importantly, the agreed-upon eligibility criteria excluded very-long-term studies that spanned the 1980s and 1990s, and large retrospective studies, limiting our reviews of questions related to long-term (≥6 months) clinical outcomes and patient-level predictors of outcomes.

We identified 21 studies (with a total of 3368 patients) in 28 publications that assessed the effectiveness of percutaneous renal angioplasty with stent placement for the treatment of ARAS and reported data on clinical outcomes. Two additional studies44,45 that reported adverse events, but not long-term outcomes were also included. The studies followed patients from 6 months to 48 months; 17 studies followed their cohorts prospectively and four studies used both prospective and retrospective study designs.

Three studies were multicenter.46–48 Eight explicitly reported consecutive patient enrollment.49–56 In seven studies patients with ARAS underwent primary stent placement;49–51,57–60 in five studies some patients with prior failed angioplasty were included (fewer than 20 percent of patients);54,56,61–63 and eight studies had no such data available. The studies mostly included patients with a mean age of 65 years and above, and those who had one or more additional atherosclerotic vascular diseases. The most common indication for angioplasty was uncontrolled hypertension while on two or more medications. Two studies included all patients with cardiovascular disease or flash pulmonary edema.58,60

The definitions of RAS varied across studies. Three included patients with over 80 percent stenosis,47,50,51 13 with over 60 percent or 70 percent stenosis,48,49,53–55,57–62,64,65 and four studies included patients with over 50 percent.52,56,63,66 The percent stenosis was not stated in one study.46

In 20 studies ARAS was diagnosed in the preoperative period by renal angiography;47–66 and in four studies digital subtraction was utilized in addition to renal angiography.47,50,60,66 One study did not report the method of preoperative diagnoses of ARAS.46 Sixteen studies reported that ostial lesions ranged from 32 to 100 percent of the involved arteries. However, the studies differed in their description of ostial stenosis, which were defined as stenosis of the renal artery within 3 mm51,53 or 4 mm66 or 5 mm49,60,63 or 10 mm48,56,61 of the aortic lumen. Patients with bilateral ARAS ranged from 9 to 50 percent.

Data on femoral or brachial approaches to access was available in 11 studies,46–48,51,54,56–58,60,63,65,66 which reported femoral as the most common access approach. The Palmaz stents were used in 14 studies;46,48,52–59,61–63,66 multiple stents including the Palmaz stents were used in six studies, 47,49,51,60,64,65 and one study did not report data on the type of stent used.50 Only one study reported utilizing a distal protection device.47 Preprocedural and procedural prophylaxis against thrombosis was reported in 16 studies with varying regimes: nine studies reported heparin only regimens,51–54,58,60,61,63,65 four studies reported combination regimens of heparin with ticlopidine, clopidogrel, or aspirin,47,48,56,64 and three other studies reported combination regimens of aspirin with dipyramidamole, clopidogrel, or warfarin.46,49,55

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater)

Data on mortality 30 days after angioplasty with stent placement was reported in 18 studies. The mortality rates ranged from 0.5 to 53 percent; seven studies reported over 10 percent mortality at follow up.46,49,51,59,61,64,66 The most common cause of mortality reported was due to cardiovascular-related deaths. Across studies, there was an expected rise in mortality with increasing duration of followup. However, by visual inspection, there appear to be two groups of studies, those with mortality rates rising from approximately 12 to 30 percent over 4 years, and those with lower mortality rates rising from 0 percent to under 10 percent over 5 years. We were unable to identify any clear factor that explained the differences in mortality rates across studies.

#### Kidney Function

Four studies reported kidney outcomes as changes in estimated glomerular filtration rate (or creatinine clearance).49,57,61,64,67 Thirteen other studies reported changes in followup serum creatinine Of these, statistically significant improvements in kidney function were observed from 12 to 24 months in three studies, statistically significant deterioration was reported in two studies, and the remaining 12 studies found no significant changes. Kidney outcomes were quantified using different definitions and categorized as improved, unchanged, and worsened in 12 studies. Improved kidney function ranged from 8 to 51 percent. Several studies noted that some patients were able to stop dialysis.

#### Blood Pressure Control

All 21 studies reported blood pressure outcomes as change from baseline and/or categories of cured, improved, unchanged, and worsened. The categories were quantified using a variety of cut-off levels of both systolic and diastolic blood pressure. The cure rates ranged from 4 to 18 percent, and the improved rates ranged from 35 to 79 percent. The studies also noted decreased use of antihypertensive medications compared to baseline.

#### Cardiovascular Outcomes

Two studies reported cardiovascular event rates, indicating that patients remain at increased risk of cardiovascular disease after angioplasty with stent placement.53,64 Gray 2002, however, reported a statistically significant reduction in the New York Heart Association of Functional Class after stent placement.58

#### Restenosis Rate

A total of 17 studies evaluated restenosis rates during follow-up.48,50–52,54–66 Of these only three studies evaluated the whole cohort of patients who underwent stent placement for restenosis at follow-up.50,58,63 A proportion of the original cohort who presented with clinical symptoms was evaluated in the remainder of the studies. Five studies reported restenosis rates per artery evaluated.48,55,56,59,61 The restenosis were diagnosed between 3 to 40 months after percutaneous interventions and the rates ranged from 10 to 21 percent. The majority of the studies used stenosis greater than 50 percent as their definition and utilized angiography to evaluate or confirm restenosis. Only one study utilized duplex ultrasound.59 The interobserver variability in diagnosing restenosis rates was examined in Bucek 2003 that noted disagreement in one patient.50 Ramos 2003 found a statistically significant higher rate of restenosis among those who had undergone stent placement for ostial lesions compared to those with nonostial lesions (27 versus 8 percent).57

#### Adverse Events (Including 30-Day Mortality)

A total of 16 studies reported adverse events immediately following angioplasty with stent intervention. The 30-day mortality was reported in 11 studies and ranged from <1 to 3 percent. A transient deterioration in kidney function following procedure was reported in 8 studies, which ranged from 1 to 13 percent, including four studies that reported contrast-induced nephropathy. A severe decline in kidney function was reported in three studies. Renal artery or parenchymal injury during procedures ranged from <1 to 10 percent in seven studies. Other complications included: major hemorrhage 1 percent (one study); renal artery occlusion or spasm 0.5 to 4 percent (five studies); false aneurysms 0.7 to 9 percent (six studies); severe bleeding 1 to 16 percent (six studies); and localized hematoma 0.4 to 10 percent (five studies).

### Key Question 2

#### Predictors of Outcomes

Fourteen of the total 21 studies evaluating treatment of angioplasty with stent placement also analyzed baseline variables and coprocedure interventions as predictors of outcomes.

##### Baseline Variables as a Predictor of Outcomes

###### Baseline kidney function

Eight studies evaluated levels of baseline kidney function as predictors of outcomes.49,52,54,57,61,64–67

Two studies (Kennedy 2003 and Lederman 2001), in multivariable analyses, found that lower baseline kidney function – defined by creatinine clearance under 40 mL/min or on a continuous scale of serum creatinine – predicted cardiovascular- and kidney-related mortality (RR = 1.9, P = 0.01) and overall mortality (OR 1.7, 95 percent CI 1.1–2.5).54,64

Gill-Leertouwer 2002 and Harden 1997 both reported that better kidney function at baseline – as indicated by serum creatinine less than 2.5 mg/dL or 4.5 mg/dL – predicted favorable clinical outcomes after stent placement.52,66

Kennedy 2003 also found that decreased baseline creatinine clearance was associated with at least one poor outcome during followup including myocardial infarction, CHF, stroke, uncontrolled hypertension, and kidney events.64

Five studies evaluated kidney function as a predictor of poor kidney outcomes with heterogeneous findings. Lederman 2001 noted that two-thirds of the patients with decreased baseline kidney function had late deterioration in kidney function after angioplasty with stent placement.54 However Tuttle 1998 found no difference in kidney outcomes between the groups stratified by baseline serum creatinine levels at 2 mg/dL.61 In contrast, Zeller 2004, in adjusted analyses, found that kidney outcomes improved statistically significant after intervention among those with more severe baseline kidney function.49 Ramos 2003 found a mixed effect, such that patients with baseline creatinine clearance below 50 mL/min had worse blood pressure control, but better kidney function improvement after angioplasty with stent placement than patients with better baseline kidney function.57 The prestenting serum creatinine level did not predict the primary outcome, changes in kidney function after stenting, in Rivolta 2005.^65^

###### Baseline severity of ARAS

Seven studies evaluated whether the presence of bilateral versus unilateral stenosis, or percent stenosis, affected the rate of poor outcomes.46,48,49,51,55,57,64,68

Two studies came to opposite conclusions regarding whether bilateral disease was a predictor of increased mortality. Dorros 2002 found that survival rates were lower with bilateral than unilateral ARAS (36 vs. 55 percent, P<0.05).46 Similarly, the survival rates were significantly lower among patients with mild to moderate chronic kidney disease and bilateral ARAS (serum creatine >1.4 vs. <2.0 mg/dL) compared to those with mild to moderate chronic kidney disease and unilateral ARAS (78 versus 68 percent, P<0.05). Kennedy 2003, however, found that bilateral stenosis at baseline was not an independent predictor of cardiovascular- and kidney-related mortality, although it was associated with at least one poor clinical outcome.64

Three of four studies reported no statistically significant differences in kidney and blood pressure outcomes between those patients with bilateral or unilateral disease after interventions;48,51,57,68 only one study55 reported baseline bilateral lesions independently predicted statistically significant benefit for blood pressure control at followup.

Zeller 2004 found that each increase in percent diameter stenosis at baseline independently predicted a decrease in serum creatinine at followup (OR 1.05 per each 1 percent increase stenosis, 95 percent CI 1.01–1.02, P=0.02).49 Thus patients with higher grade stenosis had greater improvements in kidney function after angioplasty with stent placement.

###### Baseline cardiovascular disease as a predictor

Four studies evaluated the association between various measures of baseline cardiovascular disease and either mortality, other poor outcomes, or kidney function.49,54,58,64

Three studies (Kennedy 2003, Lederman 2001, Gray 2002) reported that either baseline CHF, number of diseased epicardial coronary arteries, and moderate to severe left ventricular dysfunction were associated with either cardiovascular- and kidney-related mortality or all-cause mortality.54,58,64 However, Kennedy 2003 and Lederman 2001 also found that either baseline myocardial infarction or ejection fraction, CHF, hyperlipidemia, and global ARAS did not predict increased mortality.

Kennedy 2003 also found that baseline CHF, either CHF or chronic kidney disease as indications for an angiographic evaluation, and increased number of vessels treated by revascularization were associated with at least one poor outcome including myocardial infarction, CHF, stroke, uncontrolled hypertension, and kidney events.64

Zeller 2004 found that three-vessel CAD independently predicted a 61 percent lower probability of improved kidney function at followup after successful angioplasty with stent placement compared to those without relevant CAD.49

###### Diagnostic tests and other predictors

One study evaluated baseline resistance index as a predictor of kidney function and blood pressure after angioplasty with stent placement. Consistent with their other findings, Zeller 2004 found that patients with more severe kidney dysfunction at baseline, including resistance index over 80 percent benefited most from angioplasty with stent placement in terms of change in kidney function and blood pressure control.49

Again, consistent with their other findings, Zeller 2004 found that patients with higher baseline mean arterial pressure or higher number of antihypertensive medications had relatively improved blood pressure after angioplasty with stent placement.

In contrast, Kennedy 2003 found that beta-blocker or diuretic use at baseline were not independent predictors of cardiovascular- and kidney-related mortality. This study also found that patients with diabetes had a less favorable clinical outcome after angioplasty with stent placement.64

Two studies (Lederman 2001 and Kennedy 2003) found that age was not associated with mortality rates.54,64 Lederman 2001 also found that sex was not associated with mortality.

### Key Question 3

#### Coprocedure Interventions as Predictors of Outcomes

One study, Zeller 2004, in a multivariable analysis, simultaneous bilateral stenosis predicted improved kidney function (decreased serum creatinine) with OR = 2.57 (95% CI 1.55, 4.25).49 No other prospective study reported analyses of whether other peri-procedural interventions, such as different drugs or different approaches, affected either complications or long-term outcomes.

## Angioplasty of Atherosclerotic Renal Artery Stenosis (Tables 9-10,, Figures 2-3)

Table 9

Angioplasty for treatment of renal artery stenosis See Figure 2 (page 72) and Appendix E Figure for long-term mortality data, and Table 10 for 30-day mortality data.

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | Qual
Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%)and GFR/SCr Δ | | | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | Un Δ | Worse | Imp | Un Δ | Worse | Appl
Angioplasty with or without stent in patients with severe ARAS
Stent placed in some
Baumgartner, 2000^80^ | 179/95A | >60 | 188 | Ostial 29% | 9 mo | | 43 | | 12 | 33 | 42 | 25 | B
Prosp | [2.0] [2.9]^B^ | 37 | (188) | 1994–1998 | nd | | | | | | | | Low
van de Ven, 1999^79^ | 186/103 | >50 | 81 | Ostial 100% | 6 mo | 15 | 43 | 43 | | 13 | 65 | 20 | B
| | | | | | Stent group NS | | | | | | | B
RCT | [1.8] | 18 | (81) | 1993–1997 | nd | 4 | 44 | 51 | | 10 | 29 | 20 | High
| | | | | | No stent group | | | | | | | High
Ziakka, 2002^68^ | 177/94 | nd | 117 | Ostial 30% | 1 yr | 6 | 68 | 26 | | 18 | 55 | 27 | C
Prosp | [2.3] | 30 | (107) | 1993–1998 | nd | | | | | | | | Mod
Angioplasty with or without stent or surgery in patients with severe ARAS
Stent placed in some
Radermacher, 2001^67^ | MAP 109 | 70 | 138 | nd | 32 mo | | | | | | | | B
Prosp | 59 | nd | (nd) | 1994–1999 | up to 60 mo | | MAP Δ =−7 (P nd) | | | GFR Δ =+15 (P nd) | | | Mod

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CKD, chronic kidney disease; Imp, improved; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m2); HTN, hypertension; MAP, mean arterial pressure; mo, months; Mod, moderate; nd, no data; Prosp, prospective nonrandomized study; Qual, quality rating; RAS, renal artery stenosis; RCT, randomized controlled trial; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); yr, years.

A Evaluated n=163 at follow-up.

B CKD outcomes evaluated among those with CKD at baseline (n=107).

Table 10

Adverse events associated with angioplasty treatment of renal artery stenosis See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Baumgartner 2000^80^ | 163 (163) | Angioplasty or stent placement | | Peripheral atheroembolization 1.1% (overall) | Acute renal artery occlusion 0.5% (overall) Femoral pseudoaneurysm 1.6% (overall) | Bleeding requiring transfusion 1.6% (overall) | Death 1.6% (unrelated to procedure) (overall) | PTRA complications 3% Stent placement complications 9%
Radermacher 2001^67^ | 138 (nd) | Angioplasty or stent placement or surgical revascularization | Intimal dissections corrected with stent placement 21% | Aortic dissection 0.7% | Renal artery occlusion 2% False aneurysm requiring surgery 0.7% | | | Dislocated stent into or beyond aorta 1.4%
Ziakka 2002^68^ | 117 (107) | Angioplasty or stent placement | Transient ARF due to probable cholesterol embolism and contrast nephrotoxicity 1.7% | | | Femoral artery hematoma 5% | Patient with atheromatous disease died within 24 hours 0.9%
van de Ven 1999^79^ | 85 (85) | Angioplasty v stent placement | Transient decrease in kidney function due to radiography contrast agent 24% (Angioplasty) 21% (Stent) Kidney failure induced by cholesterol embolism 10% (Angioplasty) 10% (Stent) Renal artery injury 5% (Angioplasty) 7% (Stent) | | Renal artery occlusion: 2% (Angioplasty) 2% (Stent) Acute thrombosis 2% (Stent) Femoral artery aneurysm 5% (Angioplasty) 5% 7% (Stent) (including 1 arteriovenous fistula) | Bleeding 19% (Angioplasty) 19(%(Stent) | | Technical failure 7% (Angioplasty) 7% (Stent)
Gross 2001^44^ | 38 (nd) | Angioplasty | | | | | | No complications were observed
Spinosa 2001^45^ | 14 (nd) | Angioplasty | Contrast induced nephropathy 3% Injury to renal artery branch 0.6% | Transient mesenteric ischemia 1.3% Cerebral vascular accident 0.6% MI 0.6% | Pseudoaneurysm at puncture site 0.6% | | 2 deaths within 30 d 1.3% (1 due to cholesterol embolization, 1 unrelated to procedure)

ARAS, atherosclerotic renal artery stenosis; CKD, chronic kidney disease; CVD, cardiovascular disease; d, day; GI, gastrointestinal; MI, myocardial infarction;; N, number evaluated; nd, no data; PTRA, percutaneous renal angioplasty; RAS, renal artery stenosis; SCr, serum creatinine.

### Key Points for Angioplasty for Atherosclerotic Renal Artery Stenosis

- This review evaluated four studies of angioplasty that placed stents in some patients and included a total of 427 patients for clinical outcomes. Three studies were rated to be moderate quality (Grade B), one poor quality (Grade C).
- Overall, at baseline, patients frequently had diffuse atherosclerotic vascular diseases. The studies followed patients for 1 to 2 years after intervention. Almost one half of the studies were of moderate applicability to the populations of interest; only one study was of high applicability.
- The majority of the patients had cured or improved blood pressure rates at followup compared to baseline. However the improved kidney outcomes and mortality rates varied across the studies. No studies reported cardiovascular disease outcomes.
- Adverse events following angioplasty included 30-day mortality that ranged from 1 to 2 percent and transient decline in kidney function that ranged from 3 to 24 percent.
- A decreased baseline kidney function predicted deterioration in kidney function following intervention. A decline in kidney function was also observed with baseline resistance index of at least 80 percent or more.
- The angioplasty intervention in the presence of bilateral versus unilateral stenosis, or percent stenosis did not predict outcomes.
- No differences in outcomes were seen in studies that placed stents or no stents during angioplasty.

We identified one RCT79 and three cohort studies67,68,80 that treated ARAS with various approaches: angioplasty, angioplasty with stent placement, or surgical revascularization. Followup ranged from 6 to 32 months and included a total of 427 patients. Three studies included patients with over 60 percent stenosis.67,79,80 Fewer than 30 percent of the included patients had ostial stenosis in two studies;68,80 and the RCT included only patients with ostial stenosis.79 About 40 percent or less of the included patients had bilateral stenosis. The RCT and one nonrandomized study compared outcomes in patients who had angioplasty and angioplasty with stent placement.67,80 One study evaluated baseline resistance index as a predictor of outcomes. 67 In this study patients were categorized based on the baseline resistance index values of 80 or more and those with values of less than 80.

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater)

Data on mortality 30 days after angioplasty was reported in all four studies that ranged from 1 to 10 percent. Studies did not clearly document the most common cause of mortality.

#### Kidney Function

Only one study reported kidney outcomes as changes in creatinine clearance.67 Kidney outcomes were quantified using different definitions and categorized as improved, unchanged, and worsened in three other studies.68,79,80 Improved kidney function ranged from 10 to 33 percent. In two studies, there was no difference in kidney outcomes observed between the procedures.79,80

#### Blood Pressure Control

One study reported blood pressure outcomes as mean arterial pressure (MAP) change from baseline.67 The other three studies reported blood pressure as categories of cured, improved, unchanged, and worsened.68,79,80 The categories were quantified using a variety of cut-off levels of both systolic and diastolic blood pressure. The cure rates ranged from 4 to 15 percent, and the improved rates ranged from 43 to 68 percent. The studies also noted decreased use of antihypertensive medications compared to baseline.

#### Cardiovascular Outcomes

No study reported data on cardiovascular outcomes.

#### Adverse Events (Including 30-Day Mortality)

Six studies reported adverse events immediately following angioplasty intervention, including two studies that did not qualify for evaluation of other clinical outcomes.44,45,67,68,79,80 The 30-day mortality was reported in three studies and ranged from 1 to 2 percent. A transient deterioration in kidney function following procedure was reported in two studies (3 and 24 percent), including one study that reported contrast-induced nephropathy. Renal artery or parenchymal injury during procedures were 5 and 21 percent in two studies. Other complications included: renal artery occlusion or spasm 0.5 to 4 percent (four studies); false aneurysms 0.7 to 2 percent (four studies); severe bleeding 2 and 19 percent (two studies); and localized hematoma 5 percent (one study).

### Key Question 2

#### Predictors of Outcomes

Two studies evaluating treatment of angioplasty also analyzed baseline variables as predictors of outcomes.

##### Baseline Variables as a Predictor of Outcomes

###### Baseline kidney function

Radermacher 2001 evaluated levels of baseline kidney function as predictors of outcomes.67 This study reported that a baseline creatinine clearance of less than 40 mL/min predicted a 13-fold increased risk for a decline in kidney function at follow-up in both univariate and multivariable analyses. In addition, various factors before revascularization including proteinuria and small size of the kidneys (<9 cm) predicted worse kidney function at follow-up in univariate analyses only.

###### Baseline severity of ARAS

Ziakka 2002 evaluated whether the presence of bilateral versus unilateral stenosis, or percent stenosis, affected the rate of poor outcomes.68 This study reported no statistically significant differences in kidney and blood pressure outcomes between those patients with bilateral or unilateral disease after interventions.

###### Diagnostic tests and other predictors

Radermacher 2001 evaluated baseline resistance index as a predictor of kidney function and blood pressure after angioplasty, angioplasty with stent placement or surgical revascularization. They found that patients with resistance index above 80 percent were more likely to have worsening kidney function and less likely to have either improved blood pressure or reduced use of antihypertensive medication after revascularization, both by univariate and adjusted multivariable analyses.

The same study also found that men had less favorable clinical outcomes following revascularization.

### Key Question 3

#### Coprocedure Interventions as Predictors of Outcomes

Among the studies that used angioplasty or angioplasty with stent placement for the treatment of ARAS, there were no differences in blood pressure and kidney outcomes between the procedures.79,80 No other study reported analyses of whether other periprocedural interventions, such as different drugs or different approaches, affected either complications or long-term outcomes.

## Surgical Treatments of Atherosclerotic Renal Artery Stenosis (Tables 11-12,, Figures 2-3)

Table 11

Surgical renal artery revascularization for the treatment of renal artery stenosis

See Figure 2 (page 72) and Appendix E Figure for long-term mortality data, and Table 12 for 30-day mortality data.

Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | Results | | | | | | | | Qual
Author, Year | Mean BP | Mean % Stenosis | No. Evaluated RAS | RAS Location | Mean Duration | HTN (%) and BP Δ | | | | CKD (%) and GFR/SCr Δ | | | CVD (%) | Qual
Study Design | Mean GFR [SCr] | % Bilateral Stenosis | (ARAS) | Years Enrolled | Range | Cured | Imp | UnΔ | Worse | Imp | UnΔ | Worse | CVD (%) | Appl
Cherr, 2002^83,85–88^ | 200/104 | ≥80 % | 500 | Ostial: nd | 4.7 yr | 12% | 73% | | 15% | 43% | 47% | 10% | 74% of late deaths 2°to CVD; nonfatal events | C
Retro | 41 | 59% | (500) | 1987–1999 | 1–159 m | BP Δ = −53/−23 P<0.0001 (base) | | | | GFR Δ= 7.1 P<0.0001 (base) 17% became dialysis dependent | | | 28% (angina, MI, PTCA, CABG) | Low
Galaria, 2005^82^ | 171/82 | ≥50 % | 100 | Ostial: nd | 3.5 yr | 68% (3 yr) 59% (5 yr) | | | | | | | | C
Retro | 51 | 44% | (100) | 1984–2004 | 0–17 yr | | | | | CKD eventA = 20% (3 yr), 26% (5 yr) | | | | Low
Alhadad, 200481 | 180/100 | nd | 106 | Ostial: nd% | nd | | | | | | | | | C
Retro | nd | nd | (86) | 1987–1996 | 0–12 yr | Only mortality data reported (after 6 mo). See mortality figure | | | | | | | | Low
Marone, 2004^84^ | nd | Both cohorts ≥75% | Cohort 1:139 (139) | Ostial: nd | 48 mo | Cohort 1: kidney function improved or unchanged in 76% Cohort 2: kidney function improved or unchanged in 72% Dialysis free survival at 5 years was 55% (both cohorts?) | | | | | | | | C
Retro | Cohort 1: [>2]Cohort 2: [≥1.5] | nd | Cohort 2: 96 (96) | Cohort 1: 1980–1990 Cohort 2: 1990–2001 | 6 wk to 12.6 yr | Cohort 1: kidney function improved or unchanged in 76% Cohort 2: kidney function improved or unchanged in 72% Dialysis free survival at 5 years was 55% (both cohorts?) | | | | | | | | Low

Δ, change; Appl, applicability rating; ARAS, atherosclerotic renal artery stenosis; BP, blood pressure; CABG, coronary artery bypass graft; CKD, chronic kidney disease; CVD, cardiovascular disease; GFR, glomerular filtration rate (or creatinine clearance, mL/min or mL/min/1.73 m2); HTN, hypertension; Imp, improved; MI, myocardial infarction; mo, months; nd, no data; PTCA, percutaneous transluminal coronary angioplasty; Qual, quality rating; RAS, renal artery stenosis; SCr, serum creatinine (mg/dL); UnΔ, unchanged (or stable); wk, weeks; yr, years.

A Dialysis, CKD-related mortality, or SCr>1.5 mg/dL.

Table 12

Adverse events associated with the surgical treatment of renal artery stenosis See Figure 2 (page 72) and Appendix E Figure for long-term mortality data.

Author Year | N RAS (ARAS) | Intervention | Kidney-related | CVD-related | Thrombosis/occlusion | Bleeding | 30 d mortality | Other
Cherr 2002^83,85–88^ | 500 (500) | Surgery | | Perioperative: MI 3% Stroke 1% Significant arrhythmia 5% Nonfatal CVD 28% | | | Death: 5% | Perioperative morbidity 17% Including pneumonia 8%
Marone 2004^84^ | 325 (325) | Surgery | | | | | Perioperative mortality 6%, mostly secondary to coronary and cerebrovascular events
Galaria 2005^82^ | 247 (247) | Angioplasty-Surgery | Perioperative kidney morbidity: 0% (Angioplasty) 6% (Surgery) | Perioperative minor cardiac morbidity <1% (Angioplasty) 14% (Surgery) | | | Deaths <0. 1% (Angioplasty) (all due to cardiac events) Deaths 0.1% (Surgery) 6/10 due to cardiac complications, 3/10 pulmonary, 1/10 sepsis Major morbidity: 4% (Angioplasty) 4%(Surgery) | Technical complication rate: 18% (Angioplasty) 0% (Surgery) Pulmonary adverse events: 0% (Angioplasty) 9% (Surgery) Systemic infection: 0% (Angioplasty) 8% (Surgery) Other wound related events: 0% (Angioplasty) 6%(Surgery)
Alhadad2004^81^ | 106 (86) | Angioplasty-Surgery | | | | | 2% (Angioplasty) 9% (Surgical) | Multiorgan failure0% (Angioplasty) 2% (Surgery) Sepsis 0% (Angioplasty) 1% (Surgery)

ARAS, atherosclerotic renal artery stenosis; CVD, cardiovascular disease; d, day; MI, myocardial infarction; mo, months; N, number evaluated; RAS, renal artery stenosis; SCr, serum creatinine.

### Key Points for Open Revascularizations for Atherosclerotic Renal Artery Stenosis

- Four studies that reported outcomes of surgical treatments for ARAS met eligibility criteria. All four studies had methodological flaws making them susceptible to bias.
- All four studies reported similar long-term mortality (about 30–40 percent at 5 years).
- Two studies reported that 60–70 percent of patients had improvements in hypertension.
- One study reported 17 percent of the patients became dialysis-dependent during a mean follow up period of 56 months.
- Thirty-day mortality rate ranged from 3.7 to 9.4 percent.

Given the limited applicability of studies of surgical interventions to angioplasty with stent placement, the eligibility criteria for these studies were restricted to include only those most likely to have greater applicability. Thus, only studies that included at least some patients who had surgery after the publication of JNC-5 (1993) were included. Prospective studies with at least 10 subjects and retrospective studies with least 100 subjects were eligible. As with the limitations to the eligibility criteria for angioplasty studies, these criteria limited our review of long-term clinical outcomes (≥6 months) and patient-level predictors of outcomes.

Four studies met criteria. Two retrospective comparative studies,81,82 and two retrospective cohort studies,83,84 provided surgical outcomes in 921 patients. The comparative studies compared surgical to percutaneous interventions, but only the surgical cohorts were included here since the key questions did not relate to this comparison and the data from the angioplasty cohorts were retrospective. The mean follow up times in these studies ranged from 4 months to 56 months. All four studies were of methodological quality C (poor). The results from these studies are generally applicable to patients with hypertension, chronic kidney disease, and hemodynamically significant ARAS.

The four studies had similar inclusion criteria and reviewed similar populations of patients with ARAS with hypertension, chronic kidney disease, or both hypertension and chronic kidney disease. Galaria 2005 included only patients with at least 60 percent stenosis.82 All the patients in the study by Marone 2004 had at least 75 percent stenosis.84 Cherr 2002 reported that 41 percent of the patients had at least 80 percent ostial stenosis or occlusion.83 Alhadad 2004. did not provide explicit information regarding the stenosis. The mean age of the subjects in all studies was in the mid-60s.81

### Key Question 1

#### Mortality (Study Duration 6 Months or Greater)

Galaria 2005 reported 5-year mortality of 27 percent.82 Marone 2004 reported a 5-year mortality of about 41 percent.84 Cherr 2002 estimated 5-year and 10-year mortality for all patients at 31 and 66 percent, respectively.83 Cardiovascular events accounted for most of the late deaths (74 percent). Six-year mortality in Alhadad 2004 was 42 percent and 10-year was 62 percent.81

#### Kidney Function

Galaria 2005 reported cumulative freedom from dialysis, kidney disease-related mortality, or serum creatinine > 1.5 mg/dL was 74 percent at 5 years.82 Cherr 2002 reported that in all the patients who survived surgery, there was a significant increase in postoperative estimated GFR as compared with preoperative GFR (41 vs. 48 mL/min, P <0.0001).83 Eighty-four patients (17 percent) eventually became dialysis-dependent during the follow up period of 1 to 159 months. The median survival rate after dialysis-dependence was 18.6 months, with 27 percent of the patients alive at 5 years.

Marone 2004 reported that 72 percent of the patients in the 1990–2001 cohort, with a mean follow up of 46 months, had improved or unchanged excretory function after surgery.84 Dialysis was instituted in 16 patients from this cohort during a mean follow up of 17 months, resulting in a crude rate of progression to end-stage renal disease of 17 percent. Dialysis-free survival at 5 years was 55 percent.

#### Blood Pressure Control

Galaria 2005 reported either cured or improved hypertension in 68 percent of the patients at 3 years.82 At 5 years, 59 percent of the patients showed improvement. Cherr 2002 reported that, of the 477 patients who survived surgical repair, 12 percent were considered to have cured hypertension, 73 percent were improved, and 15 percent had failed blood pressure response.83 Blood pressure measurements were taken at 8 weeks or more after surgery.

#### Cardiovascular Outcomes

Alhadad 2004, Galaria 2005, and Marone 2004 did not report long-term cardiovascular outcomes.

Cherr 2002 reported that cardiovascular events accounted for most of the late deaths (74 percent), including coronary artery disease (41 percent), and stroke (9 percent).83 Of the late deaths, 24 percent occurred from the treatment of or complications from aneurysmal disease or noncoronary atherosclerosis. There were 218 nonfatal cardiovascular events that occurred in 139 patients (28 percent). They included angina (49 patients), myocardial infarction (29 patients), percutaneous transluminal coronary angioplasty (19 patients), and coronary artery bypass grafting (22 patients). Cerebrovascular events included transient ischemic attacks (18 patients), stroke (22 patients), and carotid endarterectomy (27 patients). Lower extremity revascularization was necessary in 11 patients. Twenty-four patients had other types of vascular reconstructions. Multivariable analysis showed that preoperative angina showed a significant and independent association with late cardiovascular morbidity rate. Neither blood pressure nor kidney function response showed an association with followup cardiovascular morbidity rate.

#### Adverse Events (Including 30-Day Mortality)

Thirty-day mortality in the four studies was 4/109 (3.7 percent),82 23/500 (4.6 percent),83 15/235 (6 percent),84 and 10/106 (9.4 percent).81

Out of the 4 deaths reported by Galaria 2005, two died from cardiac events, one from systemic infection, and one from pulmonary complications. Major morbidity from procedural complications was 4 percent. Twenty percent of the patients developed one of more of the following complications: cardiac (14 percent), respiratory (9 percent), kidney (6 percent), systemic infection (8 percent), and/or other wound-related events (6 percent).

Cherr 2002 reported that perioperative morbidity occurred in 81 patients (16 percent). These events included myocardial infarction (15 patients), stroke (5 patients), significant arrhythmia (22 patients), and pneumonia (36 patients). Five patients had worsening kidney function after operation that resulted in permanent dialysis-dependence within 1 month of surgery.

Alhadad 2004 reported that the early adverse events (deterioration or death within a month) occurred in 14 patients (19 percent) treated with open renal artery surgery. The overall procedural complication rate was 22 percent. Following 30-day complications were reported: bleeding/hematoma 7/92 (8 percent); occlusion/thrombosis 6/92 (7 percent); infection 3/92 (3 percent); distal embolization 2/92 (2 percent).

### Key Question 2

#### Predictors of Outcomes

Galaria 2005 reported that a patent vessel predicted improvement in kidney function and freedom from dialysis.82 And in all patients, preprocedure hemodialysis led to poorer functional kidney function recovery.

Cherr 2002 reported that preoperative chronic kidney disease (HR = 2.4, 95 percent CI 1.9–3.0, P <0.001), diabetes mellitus (HR = 2.1, 95 percent CI 1.2–4.0, P = 0.007), prior stroke (HR = 1.5, 95 percent CI 1.0–2.2, P = 0.04), and severe aortic occlusive disease (HR = 1.7, 95 percent CI 1.2–2.3, P = 0.003) showed significant and independent associations with death or dialysis during the followup examination period.83 After surgery, in comparison with blood pressure improved or failed, blood pressure cured was significantly and independently associated with improved dialysis-free survival rate (OR = 0.5, 95 percent CI 0.3–0.9, P = 0.01). Improved postoperative kidney function showed significant and independent associations with increased dialysis-free survival rate as compared with kidney function unchanged.

Marone 2004 reported that in logistic regression analysis, an early favorable response to surgery (OR = 16, 95 percent CI 1.6–308, P <0.0001) and the initiation of dialysis prior to surgery (OR = 22, 95 percent CI 1.6–308, P = 0.02) were positive predictors of long-term improvement in kidney function.84 Also, the probability of continued deterioration in kidney function was increased for those patients who exhibited a baseline serum creatinine of 3 mg/dL or greater.

### Key Question 3

#### Coprocedure Interventions as Predictors of Outcomes

No reviewed study reported data related to any coprocedures or differences in procedures being associated with differential outcomes.

## Summary of Direct and Indirect Comparisons of Angioplasty to Medical Therapy for Treatment of Atherosclerotic Renal Artery Stenosis

No study has directly compared angioplasty with stent placement (the most common invasive intervention for ARAS) with medical treatment. Two RCTs directly compared angioplasty without stent placement to medical treatment, with outcomes primarily reported at 6 and 12 months.18,19 A third RCT compared immediate angioplasty without stent placement to angioplasty delayed by 3 months in half the remaining patients and medical treatment alone in the other patients.15–17 The comparison between angioplasty and medical treatment alone is possible only at 3 months (shorter than the long-term duration outcomes of interest); the final comparison was reported at 12 months. The remaining seven comparative studies (one of which was a nonrandomized subgroup of one of the RCTs) compared multiple types of revascularization with a variety of medical treatments for a wide range of durations – from about 6 months to 7 years – in both prospective and retrospective studies.

Hundreds of studies of cohorts of patients receiving angioplasty, both prospective and retrospective, have been published since 1980. Of these, 21 were prospective studies that analyzed at least 30 patients who received angioplasty with stent placement mostly after 1993 and reported long-term (≥6 months) outcomes of interest; an addition four studies followed at least 30 patients who had angioplasty either with or without stent placement. Few studies specifically evaluated the effect of medical treatments that are currently commonly in patients with ARAS. Only four cohort studies evaluated ACE inhibitors or “triple therapy,” treatment with three classes of antihypertensive agents. An additional eight natural history studies evaluated cohorts of patients who mostly received medical treatment (although for the most part this is not clear).

All the studies reviewed either implicitly or explicitly included only patients with generally stable blood pressure, kidney function, and cardiovascular status. Patients with acutely decompensation due to progressive ARAS were not included.

### Mortality (Study Duration 6 Months or Greater)

#### RCTs of Angioplasty vs. Medical Treatment

Only the SNRASCG randomized trial (Webster 1998) reported mortality data.18 Over 0 to 42 months, the survival curves were nearly identical for those randomized to medical therapy (30 patients) or angioplasty (25 patients).

#### Other Direct Comparisons

In two other studies that directly compared similar patients who received either renal artery revascularization or medical treatment alone, no difference was found in mortality up to about 5 years.

#### Cross-Study (Indirect) Comparisons

Mortality rates (Figures 1–2) were grossly similar across angioplasty studies, medical treatment studies, and natural history studies. There were four studies, particularly among the natural history studies, that reported mortality rates within 6 years over 40 percent,38,41–43 however, three of these studies had such high mortality rates only among those with either high-grade stenosis (>75 percent) or bilateral disease.

### Kidney Function

#### RCTs of Angioplasty vs. Medical Treatment

Both RCTs found no clinical or statistically significant differences in kidney outcomes.

#### Other Direct Comparisons

Seven other studies with direct comparisons between revascularization and medical treatment mostly agreed in their findings of no clinical or statistically significant differences in kidney outcomes. Exceptions included the DRASTIC study (van Jaarsveld 2000) which found a modestly higher rate of worsened kidney function among those with delayed or no angioplasty, but no difference in mean creatinine clearance, and a prospective study that found a modest, but significant relative improvement in serum creatinine after revascularization compared to medical treatment.

#### Cross-Study (Indirect) Comparisons

Among 17 angioplasty with stent placement cohort studies, improved kidney function ranged from 8 to 51 percent, there were small to modest changes in creatinine clearance (−2 to +8 mL/min) or serum creatinine (−0.1 to +0.2 mg/dL). Only a single cohort study of medical treatment reported change in serum creatinine over an average of 1.5 years, which rose by 0.3 mg/dL. Seven natural history studies also found similar increases in serum creatinine or progressive decreases in kidney function.

Among the 17 angioplasty with stent placement cohort studies many found similar changes in kidney function as the medical and natural history studies, however, only in some of the angioplasty with stent placement studies were patients found to have improved kidney function. This implies that, at least in a subset of patients with ARAS, kidney function is more likely to improve after angioplasty than with continued medical treatment.

### Blood Pressure Control

#### RCTs of Angioplasty vs. Medical Treatment

Of the two RCTs, one found a clinically and significantly larger decrease in blood pressure after angioplasty than medical treatment in patients with bilateral disease, but a nonsignificantly larger decrease in systolic blood pressure in those patients with unilateral disease who were treated medically, rather than with angioplasty. This study also found no difference in the number of antihypertensive drugs required at followup in both sets of patients, regardless of intervention. The other RCT found a modestly greater decrease in both systolic and diastolic blood pressure after angioplasty, but only the change in diastolic pressure was statistically significant compared to medical treatment. In addition, after angioplasty patients required about half as many antihypertensive drugs.

#### Other Direct Comparisons

Six of the seven other comparative studies that reported blood pressure outcomes found no significant difference in blood pressure control, regardless of intervention. Although one of these found a nonsignificant decrease in blood pressure medication use after angioplasty, in contrast to a significant small increase in medication use in those patients treated only medically. In addition, two of these studies found larger, though nonsignificant, decreases in blood pressure among those patients who did not receive revascularization. Only one problematic, retrospective study reported a significant difference in blood pressure control, such that twice as many patients had improved blood pressure control after angioplasty, with or without stent placement, than with medical treatment alone.

#### Cross-Study (Indirect) Comparisons

The 21 angioplasty with stent placement cohort studies found that between 4 and 18 percent of patients were cured of hypertension (generally defined as maintaining blood pressure control without medication); although two comparative studies of angioplasty that placed stents in some patients found that no patients were cured after revascularization. Neither medical nor natural history studies reported cure, improvement, or worsening blood pressure rates, possibly implying very small or no “cures.”

Across all angioplasty studies, after revascularization with stent placement, blood pressure fell between 6–32/0–17 mm Hg. Blood pressure changes were actually larger among the one medical and seven natural history studies, where blood pressure generally decreased by 20–50/8–42 mm Hg. However, because of differences in antihypertensive treatments both within and between studies, it is impossible to draw conclusions about the relative effect on blood pressure measurements of the different interventions.

### Cardiovascular Outcomes

#### RCTs of Angioplasty vs. Medical Treatment

Only the SNRASCG study(Webster 1998) reported cardiovascular outcomes. No difference was found in event rates for CHF, stroke, or myocardial infarction, regardless of intervention, up to 54 months of followup.

#### Other Direct Comparisons

Only one other comparative study reported an outcome that included cardiovascular events. In an RCT of revascularization surgery to medical treatment in patients with high-grade stenosis, almost identical rates were found of a combined outcome of atherosclerotic cardiovascular event, death, diastolic hypertension, or worsening kidney function.

#### Cross-Study (Indirect) Comparisons

The reporting of cardiovascular outcomes in cohort studies was inadequate to allow cross-study comparisons. No study of medical interventions reported cardiovascular outcomes.

### Restenosis Rate

A total of 17 studies of angioplasty with stent placement evaluated restenosis rates during follow-up between 3 to 40 months. Of these only three studies evaluated the whole cohort of patients who underwent stent placement for restenosis at follow-up. A proportion of the original cohort who presented with clinical symptoms was evaluated in the remainder of the studies. The restenosis rates ranged from 10 to 21 percent. Only one study noted a statistically significant higher rate of restenosis among those who had undergone stent placement for ostial lesions compared to those with nonostial lesions (27 versus 8 percent).

### Adverse Events (Including 30-Day Mortality)

#### RCTs of Angioplasty vs. Medical Treatment

Neither RCT compared adverse event rates between interventions.

#### Other Direct Comparisons

No study reported adverse events related to medical treatment, precluding comparisons. One early retrospective study reported that 30-day mortality was similar in both groups of patients.

#### Cross-Study (Indirect) Comparisons

Adverse events reported in angioplasty studies included 30-day mortality of <1 to 3 percent, transient deterioration of kidney function, renal artery or parenchymal injury, periprocedural cardiovascular events, hemorrhage and hematomas, and renal artery occlusion. Medical studies did not report 30-day mortality. Adverse events related to blood pressure medications (ACE inhibitors, beta blockers, and hydralazine) included orthostatic hypotension, central nervous system symptoms, digestive symptoms, Raynaud’s phenomenon, and others.

### Predictors of Outcomes

#### RCTs of Angioplasty vs. Medical Treatment

Neither RCT directly analyzed whether any baseline predictors, including diagnostic tests, would predict relative outcomes between interventions. Although, in the SNRASCG study (Webster 1998), patients with bilateral stenosis had larger decreases in blood pressure after angioplasty than with medical treatment, in contrast to patients with unilateral disease.

#### Other Direct Comparisons

The DRASTIC study (van Jaarsveld 2000), comparing early versus either delayed or no revascularization, found that in contrast to patients with unilateral disease, patients with bilateral disease had better improvement in diastolic blood pressure, but not in creatinine clearance. Captopril test, renogram, recent hypertension, and stenosis greater than 80 percent were not predictors of either worse outcome overall or of which intervention would result in better outcomes.

#### Cross-Study (Indirect) Comparisons

Cohort studies of angioplasty with stent placement found that various baseline variables related to degree of ARAS, coexisting cardiovascular disease, kidney function, and demographics were (or sometimes were not) associated with likelihood of outcomes after the start of an intervention. However, these analyses cannot determine which predictors would be useful to differentiate those patients who might have better outcomes with or without revascularization.