# Methods

## Technical Expert Panel

This report on the comparison of aggressive medical therapy to angioplasty with stenting for the management of atherosclerotic renal artery stenosis (ARAS) is based on a systematic review of the literature. The Tufts-NEMC EPC held teleconferences with a Technical Expert Panel (TEP) formed for this project. The TEP served in an advisory capacity for this report, helping to refine key questions, identify important issues, and define parameters for the review of evidence. The TEP included nephrologists, a vascular surgeon, an interventional radiologist, and the task order officer from AHRQ.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the key questions. We searched MEDLINE® (1966-September 6, 2005) for English language studies of adult humans to identify articles relevant to each key question. We also reviewed reference lists of related systematic reviews and selected narrative reviews and primary articles. In electronic searches, we combined terms for renal artery stenosis (RAS), renal hypertension, and renal vascular disease, limited to adult humans, and relevant research designs (see Appendix A for complete search strategy). We invited TEP members to provide additional citations. We did not search systematically for unpublished data.

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Results published only in abstract form are not included in our reviews because adequate information is not available to assess the validity of the data and these reports have generally not been peer-reviewed.

### Population and Condition of Interest

We included studies of adults (≥18 years) with RAS, as defined by the study authors, whether unilateral, bilateral, or in patients with a solitary functioning kidney. Where possible, we focused on studies of patients with ARAS. We thus excluded studies of fibromuscular dysplasia, arteritis-associated RAS, acute embolic stenosis, and other nonatherosclerotic stenosis. However, we included studies with mixed populations so long as at least 80 percent of subjects with RAS had atherosclerotic disease. Studies that that did not report how many patients had ARAS were generally included unless we inferred that many patients did not have ARAS. Studies that included less than 80 percent subjects with ARAS, but that reported results separately for the subgroup of subjects with ARAS were included.

We excluded studies that evaluated patients with RAS in the setting of a transplanted kidney, renal artery aneurysms (requiring repair), aortic disease requiring invasive intervention, or concurrent cancer (including renal cell carcinoma). We also excluded studies of patients who had previous surgical or angioplasty interventions for RAS.

### Interventions of Interest

The primary interventions of interest were “aggressive medical therapy” – defined as antihypertensive drugs, antilipid (lipid lowering) drugs, and antiplatelet drugs – and angioplasty with stent placement. There was consensus among the TEP members that the currently accepted invasive intervention for ARAS in the large majority of patients in the United States is angioplasty with stent. However, it was recognized that the large majority of the published evidence on angioplasty for RAS includes a wide variety of specific interventions and that limiting the review to analyses of patients who received only angioplasty with stent would be insufficient to assess the topic.

In addition, because of the known limitations and heterogeneity of the literature base, and to elicit a better understanding of the effect of a range of interventions for RAS, it was decided to broaden the interventions of interest to include both “natural history” studies that include patients receiving any intervention (or none) and studies of surgical interventions. However, in order to focus on those surgical studies that evaluated patients for whom a choice between medical treatment or angioplasty would be considered, we excluded studies of patients who required surgery for related conditions, such as aortic revascularization or valvular repair. Similarly, we excluded studies of surgical procedures that are not comparable to angioplasty, such as endarterectomy, renal ablation or nephrectomy, and revascularization of an occluded atrophic kidney (which is not generally feasible by angioplasty).

### Comparators of Interest

Given the known paucity of comparative studies, we included both uncontrolled and controlled studies, with any comparator.

### Outcomes of Interest

With the TEP, we analyzed clinical and surrogate outcomes of greatest interest regarding the comparison of medical and angioplasty interventions. It was agreed that given the chronicity of the disease process, only long-term outcomes and adverse effects were of interest. For the purposes of this report, “long-term” was defined as at least 6 months, although it was agreed with the TEP that results at 12 months or more are of greater interest.

Outcomes of interest included:

- Mortality due to all causes
- Change in kidney function
  - - Need for renal replacement therapy
  - - Categorization into “improved,” “stable,” or “worsened” kidney function or similar categories, as defined by the study authors
  - - Change in glomerular filtration rate (GFR), creatinine clearance, or serum creatinine
- Change in blood pressure control
  - - Hypertensive crises and other hypertension-related clinical events
  - - Categorization into “improved,” “stable,” or “worsened” hypertension, or similar categories, as defined by the study authors
  - - Change in the number of antihypertensive medications used
  - - Change in blood pressure
- Restenosis after angioplasty with stent placement, as defined by authors
- Flash pulmonary edema or congestive heart failure events
- Other cardiovascular events, including
  - - Cardiac events
  - - Cerebrovascular disease events
  - - Peripheral vascular disease events
- Adverse events, including, but not restricted to
  - - In-hospital and 30-day postprocedure deaths
  - - Major and minor peri- and postprocedure events
  - - Major and minor drug-related adverse events

For questions 2 and 3 we also included subgroup and regression analyses that compared preintervention patient and intervention characteristics and outcomes of interest. These included, but were not limited to, patient demographics; clinical, imaging, laboratory, and anatomic characteristics of the RAS; and treatment variables such as periprocedural medications, type of stent, use of distal protection devices, or other adjunct techniques. We extracted details from studies that reported analyses on the likelihood of outcomes based on the presence of patient or procedure related variables (e.g., that compared death rates among patients with high or low kidney function), but we extracted only the reported statistical significance of analyses that compared mean values of the variables in patients with dichotomized outcomes (e.g., that reported mean age of those who lived and those who died). These latter analyses were not considered to be sufficiently helpful for a clinician making a decision of which intervention to recommend to a given patient.

When outcomes were reported at multiple time points, we included those that occurred at 6 months, 12 months, and each subsequent year, so long as there were at least 10 subjects being evaluated.

### Years of Intervention of Interest

The TEP had numerous discussions regarding the applicability of the literature to American patients in 2006 and after. It was noted that there continue to be many changes and advances in the management of patients with RAS. In particular the successful control of patients’ blood pressure has improved greatly with the introduction of the angiotensin converting enzyme (ACE) inhibitors starting in the early 1990s, and subsequently angiotensin receptor blockers (ARBs). In addition, with the publication of the Fifth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC-5) in 1993, greater emphasis was placed on attempting to achieve lower blood pressure levels than earlier sets of recommendations. In addition, it was recognized that there have been major shifts in the types of procedures that patients are receiving for ARAS. In particular, surgical intervention is currently rare, except in the setting of coexisting conditions such as aortic or renal artery aneurysm. In addition, the placement of stents is becoming more common. Furthermore, there continue to be advances and shifts in the diagnostic tools for determining the severity of ARAS.

Given these changes in diagnosis and treatment of ARAS, it was determined that older studies are of limited applicability to making decisions concerning ARAS in the modern era. A threshold at 1993 was chosen because 1) this was the year of publication of JNC-5; 2) it was the approximate time when ACE inhibitors and subsequently ARBs began to be commonly used; and 3) this coincided with the timeframe when placement of stents became more common and surgical intervention became less common. Thus, with exceptions enumerated below, studies published in or before 1993 or that included subjects whose interventions all occurred prior to 1993 were excluded.

### Study Designs of Interest

Given the known sparseness of randomized, or even nonrandomized, comparative trials it was agreed to include uncontrolled single arm cohort studies (also known as pre-post studies). Initially, the plan was to include only prospective studies that evaluated at least 30 subjects in order to both minimize the bias related to retrospective analyses and to set a minimum level of power and applicability. However, eligibility criteria were broadened for several specific topics, as enumerated below, due to sparseness of data.

### Specific Eligibility Criteria for Different Topics

#### Comparative studies

For studies that compared either a specific medical intervention or natural history to either angioplasty or surgery, we included studies of any study design, whether prospective or retrospective, so long as at least 10 subjects were evaluated. For studies that compared medical treatment to angioplasty, we included studies regardless of enrollment date. For studies of either natural history or surgery, that were of lessened applicability due to the interventions used, only studies that included patients whose interventions occurred in 1993 or later were eligible. Any comparative study that failed to meet eligibility criteria was also examined to determine whether individual cohorts of subjects (e.g., the natural history arm alone) may be eligible for other sections of the review.

#### Angioplasty studies

The large majority of available articles on ARAS reported on cohorts of subjects who received angioplasty. Given the large number of studies, only cohort studies of angioplasty with stent placement were eligible. Studies in which only some patients received stents were included, but studies of only angioplasty without stent placement were excluded. It was further agreed to limit these studies based on the minimal quality criteria of prospective studies with at least 30 patients evaluated, at least some of whom had the procedure performed in 1993 or later. In addition, because the primary questions of interest pertain to patients with ARAS who have not had a previous invasive intervention, we excluded studies in which more than 20 percent of the subjects had a previous procedure.

#### Medical intervention and “natural history” studies

Studies of specific medical interventions were separated from studies that evaluated patients who received a mix of interventions. These latter, natural history, studies usually described the interventions poorly, if at all. While an attempt was made to distinguish studies of a variety of only medical treatments from those that followed people regardless of intervention (including angioplasty, surgery, or both), this was not always feasible. For medical intervention studies, we included only prospective studies of antihypertensive, antilipid, or antiplatelet medications with at least 10 subjects who received treatment at any date. For natural history studies, we included both prospective and retrospective studies with at least 10 patients, at least some of whom were followed in 1993 or later.

#### Surgery studies

Studies of surgical interventions of any study design, whether prospective or retrospective, were included. To be eligible, surgical studies had to include at least some patients who had their procedure in 1993 or later. Prospective studies with at least 10 subjects and retrospective studies with at least 100 subjects were eligible.

## Data Extraction

Items extracted included first author, year, country, setting, funding source, study design, inclusion, and exclusion criteria, including study definitions of RAS and ARAS (see Appendix B for a sample data extraction form). For randomized controlled trials (RCTs), we recorded the method of randomization, allocation concealment, blinding, and whether results were reported on an intention-to-treat basis. Specific population characteristics included demographics such as age and sex, blood pressure, mean percent renal artery stenosis, percent of subjects with bilateral stenosis, and kidney function. Details regarding angioplasty techniques, including type of stent, surgical techniques, and/or medical interventions were also extracted.

For each outcome of interest, baseline, followup, and change from baseline data were extracted, including information of statistical significance. For most outcomes, only data from the last reported time point were included. Mortality data from all 6-month intervals from baseline and the final value were extracted. When outcome data were reported as overall outcomes, without a specific time point, the mean or median time of followup was used. All adverse event data were extracted.

For studies that reported any analyses of any predictors of outcomes (related to Key Questions 2 and 3), full data were extracted for each predictor of interest when analyses were performed from the perspective of the predictor (e.g., sex as a predictor of death). Multivariable analyses were preferred over univariate analyses. When analyses were performed from the perspective of the outcomes (e.g., average baseline age of those who died and survived), only the statistical significance of the association was extracted.

## Quality Assessment

We assessed the methodological quality of studies based on predefined criteria. We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts-NEMC EPC as well as in evidence-based clinical practice guidelines.13,14 This system defines a generic grading system that is applicable to varying study designs including RCTs, nonrandomized comparative trials, cohort, and case-control studies. For RCTs, we mainly considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described, as well as clearly reported. Only RCTs could receive an A grade. For nonrandomized trials and prospective and retrospective cohort studies, we used (as applicable) the report of eligibility criteria, and the similarity of the comparative groups in terms of baseline characteristics and prognostic factors, the report of intention-to-treat analysis, and the crossovers, important differential loss to followup between the comparative groups or overall high loss to followup, the validity, and the adequacy of the description of outcomes and results.

### A (good)

Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.

### B (fair/moderate)

Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

### C (poor)

Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information, or discrepancies in reporting.

## Applicability Assessment

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (e.g., disease status, age, comorbidities). Some may be implicit or due to unintentional biases, such as those related to location (e.g., multicenter vs. single center, hypertension clinic vs. surgical practice), intervention (e.g., stent or no stent placement, which antihypertensive agents were used, angioplasty vs. surgery), factors resulting in study withdrawals or issues related to compliance with stated criteria, and other issues. The applicability of a study is dictated by the key questions, the populations, and the interventions that are of interest to this review, as opposed to those of interest to the original investigators.

To address this issue, we categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

High | Sample is representative of the target population. It should be sufficiently large to cover a range of ARAS severity, including percent stenosis, percent with bilateral stenosis, blood pressure, and kidney function. The mean values of these parameters should be at least broadly similar to the mean for the typical patient receiving treatment for ARAS. In addition, the intervention should be applicable to currently used interventions, including angioplasty with stent placement and/or those antihypertensive drugs currently used commonly. At least 30 subjects analyzed.
Moderate | Sample is representative of a relevant subgroup of the target population, but not the entire population, or interventions used were similar to those of primary interest to this review (e.g., angioplasty without stent placement). Limitations include such factors as narrow age range, inclusion of patients without ARAS, atypically high blood pressure, or serum creatinine.
Low | Sample is representative of a narrow subgroup of subjects only, and is of limited applicability to other subgroups. For example, a study of a surgical intervention or mostly from the early 1980s when ACE inhibitors, calcium antagonists, and beta-blockers were either not or rarely used.

## Data Synthesis

As described in the Results section, the reviewed studies were highly heterogeneous in terms of interventions, study designs, and outcomes. In addition, only two randomized controlled trials fully met eligibility criteria. Given these limitations, and the relatively limited value of the cohort studies to fully answer the key questions, it was agreed with the TEP that all analyses would be descriptive and metaanalytic techniques would not be applied.

### Summary Tables

Summary tables succinctly report summary measures of the main outcomes evaluated. They include information regarding study design, interventions, mean blood pressure, kidney function, percent renal artery stenosis, bilateral RAS and ostial lesions, number of subjects analyzed, including the number with ARAS, mean study duration and range, years of intervention, quality and applicability, and principal blood pressure, kidney function, and cardiovascular disease outcomes of interest.

Data on mortality were compiled across studies into a separate table and graphs. Data on adverse events were also compiled into a separate set of tables.

### Overall Comparative Synthesis Table

To aid discussion, we summarized the comparative data (both direct and indirect comparisons) in one table in Chapter 4. Separate cells were constructed for each key question. Important comparative findings for each key question were summarized whenever the data were available.

### Grading a Body of Evidence for Each Key Question

We assigned an overall grade describing the body of evidence for each key question that was based on the number and quality of individual studies, duration of followup and the consistency across studies. The grades corresponded to the following definitions:

Robust – There is a high level of assurance with validity of the results for the key question based on at least two high quality studies with long-term followup of a relevant population. There is no important scientific disagreement across studies in the results for the key question.

Acceptable – There is a good to moderate level of assurance with validity of the results for the key question based on fewer than two high quality studies or in high quality studies that lack long-term outcomes of relevant populations. There is little disagreement across studies in the results for the key question.

Weak – There is a low level of assurance with validity of results for the key question based on either moderate to poor quality studies or on studies of a population that may have little direct relevance to the key question. There could be disagreement across studies in the results for the key question.

The grades provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, they may oversimplify the many complex issues involved in appraising a body of evidence. The individual studies involved in formulating the composite grade differed in their design, reporting, and quality. As a result, the strengths and weaknesses of the individual reports addressing each key question should also be considered, as described in detail in the text and tables.

## Peer Review

A draft version of this report was reviewed by a panel of expert reviewers (see Appendix D), including representatives from the American College of Cardiology, the Society for Cardiovascular Angiography and Intervention, the pharmaceutical industry, and the Food and Drug Administration. The reviewers included experts in cardiology, interventional radiology, vascular surgery, nephrology, and vascular disease. These experts were either directly invited by the EPC or offered comments through a public review process. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports were also reviewed by staff from the Scientific Resource Center at Oregon Health and Science University. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.