# Detailed Summary Table

## Detailed Summary Table

Table

Summary of medical, angioplasty and surgical treatments

| Angioplasty (or Surgery) vs. Medical Treatment | Medical/Natural history | Angioplasty | Surgical
Data Source | - 4 RCTs (1 a mix of medical treatment and delayed angioplasty) | - 4 RCTs (1 a mix of medical treatment and delayed angioplasty); - 6 nonrandomized comparative studies of medical treatment, 4 prospective, 2 retrospective; - 3 prospective cohort studies with medical treatments for blood pressure control; - 8 cohort studies (6 prospective, 1 retrospective, and 1 mixed) of natural history or nonspecified medical treatments | - 3 RCTs; - 6 nonrandomized comparative studies, 4 prospective, 2 retrospective; 2 included surgical revascularization; - 20 prospective cohort studies with stent placement; - 4 prospective cohort studies that used various approaches | - 1 RCT (versus medical treatment); - 2 retrospective comparisons with percutaneous angioplasty; - 2 retrospective cohorts
Population studied | - See other columns | - Medical treatment studies included patients with hypertension, mean blood pressure 172–180/103–106.; - One study included patients with >50% stenosis, half of whom had bilateral disease. One included a population where 25% had bilateral disease, though the definition of RAS was unclear. The third study did not describe degree of stenosis or bilateral disease.; - In two studies the mean serum creatinine was 1.3 mg/dL.; - Patients had mean ages approximately in the mid-50s; however, all studies included patients in their 20s or younger.; - In all three studies either some patients did not have ARAS or this was not reported.; - All 3 studies were from the 1980s or earlier.; - In the 8 natural history studies, populations studied were patients with RAS who received no revascularization interventions and presumably were under standard care by their physician.; - The mean serum creatinine levels ranged from 1.2 to 3.2 mg/dL at baseline, implying at least stage 2 chronic kidney disease.; - The mean stenosis ranged from greater than 20% to greater than 75%.; - The percentage of bilateral stenosis ranged from 17% to 100%.; - Mean blood pressure ranged from 143–179/77–102, although several studies did not report blood pressure.; - The mean age was around 70 years in most studies, though 1 study followed younger patients, between 34–55 years.; - Patients were followed from the 1970s through the late 1990s; although several studies did not report time periods. | - Patients with ARAS with HTN as the most frequent indication. Also included patients with CKD, CHF; - About 1/3 of studies included patients populations with >50% stenosis, about 1/4 included only >70% stenosis. Other thresholds were also used.; - Mostly populations with both uni- and bilateral disease, range of bilateral disease generally 25–50% of patients; some populations of unilateral or bilateral disease only.; - Comparative studies mostly had about 50% with ostial disease, when reported; cohort studies mostly with about 75% or more with ostial disease.; - Mean age generally about 65.; - Mean blood pressure generally in the range of 160–180/90–100.; - Mean serum creatinine generally in the range of 1.5–2.4 mg/dL, or mean GFR about 55 mL/min.; - Comparative studies almost all did not use stents and included populations from the 1980s and 1990s. 80% of cohort studies used stents and all included populations from the mid 1990s and later. | - Patients with ARAS with HTN, CKD, or both HTN and CKD; - Populations had ≥60% to ≥80% stenosis; - Populations had unilateral and bilateral diseases; the range of bilateral disease was 40–60%; - Mean age was in the 60s; - Mean blood pressure was in the approximate range of 175–200/85–105; - Mean serum creatinine was in the approximate range of 1.5–2.5 mg/dL; - The interventions occurred from 1980–1999
Limitations | - Only 2 RCTs compared angioplasty to medical treatment. Neither used stents. Both were of short duration (16-month, 1 with main analyses at 12 months, but patients followed from 3–54 months).; - Other comparative studies were nonrandomized, retrospective, and/or evaluated interventions of secondary interest | - Data on medical treatments or natural history were from cohort studies without controls.; - Populations studied were highly heterogeneous, limiting comparability across studies.; - 3 studies on medical treatments reported only outcomes of blood pressure control and limited data on mortality and kidney function.; - Treatments were not specified in 8 natural history studies.; - Limited data on cardiovascular outcomes. | - Majority of data on angioplasty from before-after intervention studies (cohorts) without controls; - Generally short duration of followup, often only single average time estimates of outcomes, despite range of followup time within studies.; - Very limited data on cardiovascular outcomes.; - Analyses of baseline variables as predictors of outcomes frequently inadequate. | - Retrospective cohort studies
Mortality | - In the 3 comparative studies with similar patients receiving each intervention, mortality was similar with angioplasty or angioplasty/surgery and with medical treatment. | - 3 natural history studies found that between 1/3 and 2/3 of patients died within 4–5 years.; - Among 6 studies with medical treatment (4 comparative), wide range of mortality estimates across studies, from 0–12% at 6–9 months, and 3–38% at 1 year, and 19–69% at 2–3 years. | - Wide range of mortality estimates across studies, from 1–20% at 6 months, and 0.5–23% at 1 year, and 2–53% at about 2 years. Most studies, though reported only a single mortality rate at an unspecified time point.; - Cardiovascular related death was the most frequent reported cause | - 5-year mortality ranged from 12–41% in studies that used surgical revascularization or both surgery and angioplasty.
Kidney outcomes | - No difference in kidney function (change in serum creatinine or GFR, worsening kidney function, need for dialysis) after revascularization compared to medical treatment in all but one study. One prospective nonrandomized study found a significant difference between a small decrease in serum creatinine (−0.5 mg/dL) after revascularization and a modest increase (+1.0) on medical treatment. | - Kidney function outcomes were reported in seven studies (1 medical treatment and 6 natural history studies). In general patients’ kidney function deteriorated over time, although to different degrees in the different studies. | - Among cohort studies the improved kidney function ranged from 8–51% with the majority of studies reporting statistically non significant improvements in serum creatinine; - Kidney function improvement varied among those with lower baseline kidney function | - 17 % of patients became dialysis- dependent during the follow up (2 studies)
Blood pressure outcomes | - Comparative studies heterogeneous regarding relative effect of interventions on blood pressure.; - One RCT of angioplasty vs. medicine found a significant net improvement with angioplasty among patients with bilateral, but not unilateral, disease. The second RCT found a net decrease in both systolic and diastolic blood pressure with angioplasty, but only the change in diastolic pressure was statistically significant. This study also found that after angioplasty, patients required fewer anti-HTN drugs; which was not found in the first RCT.; - Most other comparative studies found no difference in blood pressure outcomes, regardless of intervention; however 2 found that blood pressure decreased more in patients on medical treatment than after angioplasty, although this effect was not significant. | - All three studies of medical treatments for blood pressure control showed that, on average, the various treatment regimens examined were effective for lowering blood pressures in RAS patients to normal ranges.; - Outcomes of blood pressure control were reported in two natural history studies. The results were not comparable due to substantial differences in the RAS populations examined. | - The cure rates for BP outcome ranged from 4–18%, and the improved rates ranged from 35–79%. The studies also noted decreased use of anti- HTN medications compared to baseline. | - 60 – 70% of patients reported improvements in HTN (2 studies)
CVD outcomes | - 1 RCT of angioplasty vs. medical treatment and 1 RCT of surgery vs. medical treatment both found no differences in CVD outcomes, regardless of treatment. | - CHF events 13% and strokes 13% over 3–54 months (1 study); - CVD stop point (including hypertension, death, and also dialysis) 67% at about 6 years (1 study); - One natural history study reported eight fatal cardiovascular events in 20 patients with severe stenosis (≥ 75%) during 3 to 36 months followup. | - CHF events 9%, strokes 4%, and MI 4% over 3–54 months (1 study); - CVD stop point (including hypertension, death, and also dialysis) 68% at about 6 years (1 study); - CHF 20%, MI 11%, and stroke 7% at a mean of 21 months (1 study); - MI 5% at 15 months (1 study); NYHA class changed by – 1.4 at 21 months, which was a significant improvement from baseline (1 study) | - Cardiovascular events accounted for most of the late deaths (1 study); - Nonfatal cardiovascular events occurred in 28% of patients at an average of almost 5 years (1 study)
Adverse Events | - Comparative studies did not address the relative adverse events or complications between interventions (except that 30-day mortality was similar in one study, 3% vs. 5%). | - No study reported the 30-day mortality.; - A wide variety of adverse effects were reported for the use of enalapril, timolol, hydralazine, and captopril; - None of the 8 natural history studies reported adverse events | - The 30-day mortality ranged from 0–3%.; - A transient deterioration in kidney function following procedure was reported ranged from 1–24% that included contrast-induced nephropathy. Severe decline in kidney function was also noted.; - Renal artery or parenchymal injury during procedure ranged from 1–10%.; - Periprocedural acute myocardial infarction ranged from 1–7%.; - Other complications included: major hemorrhage; renal artery occlusion or spasm; false aneurysms; severe bleeding; and localized hematoma | - 30-day mortality ranged from 4–9%; - Procedural complication rate was significantly higher in combined renal artery and aortic reconstruction compared with renal artery reconstruction alone (2 studies)
Factors that influence outcomes | - The study comparing immediate to delayed or no angioplasty found that of two diagnostic tests, recent hypertension, bilateral stenosis, and severe stenosis (>70%), only bilateral disease was found to be associated with better creatinine clearance at 12 months in those patients who had immediate angioplasty, in contrast to those with unilateral disease, where creatinine clearance was statistically similar in the two groups. | - Among cohort studies of medical treatment, no analyses evaluated baseline variables as predictors.; - 4 natural history studies analyzed various predictors of mortality and/or outcomes of kidney function. Percent stenosis and baseline kidney function were f predictors of death (or dialysis) in separate studies. Another study found that nonspiral blood flow in the renal arteries predicted kidney function deterioration. Other variables related to cardiovascular disease were also found to predict death. 1 study found that bilateral versus unilateral disease did not predict progressive kidney disease. 1 natural history study found that patients with bilateral disease had higher CVD mortality. | - Worse baseline kidney function was associated with increased mortality, poor clinical outcomes, and relatively worse blood pressure after revascularization.; - History of, or markers of, cardiovascular disease was associated with increased mortality, poor clinical outcomes, and relatively worse kidney function after revascularization. | - Preprocedure hemodialysis led to poorer functional kidney recovery but initiation of dialysis prior to surgery was predictive of long-term kidney function improvement in another (2 studies); - Preoperative CKD, DM, prior stroke, and severe aortic occlusive disease showed significant and independent associations with death or dialysis during the follow up (1 study)
Factors with no effect | - The study comparing immediate to delayed or no angioplasty found that no variable predicted relative effectiveness of intervention strategy when diastolic blood pressure was the outcome.; - The randomized trial of surgical versus medical treatment, found that demographic factors did not help to predict which patients would fare better with either intervention. | | - Age and beta blocker or diuretic use at baseline were not significant predictors of mortality or other clinical outcomes.; - Baseline captopril test, renogram, arterial norepinephrine, and ACE genotype were generally not associated with outcomes.; - The association between baseline predictors and outcomes was uncertain for several factors including baseline kidney function as a predictor of followup kidney function, baseline cardiovascular disease as a predictor or blood pressure effect, percent stenosis before angioplasty, bilateral vs. unilateral RAS, and sex.
Periprocedural factors | - N/A | - N/A | - Among the studies that used angioplasty with and without stent, there were no differences in blood pressure and kidney outcomes between the procedures.; - No study reported analyses of whether other periprocedural interventions, such as different drugs or different approaches, affected either complications or long- term outcomes. | - N/A
Overall Summary | - The 2 applicable RCTs found no difference in kidney cardiovascular, or mortality outcomes between angioplasty without stent placement and medical treatment. The studies suggest a better reduction in blood pressure control after angioplasty, particularly in patients with bilateral disease. | - Data on medical treatments or natural history were from cohort studies without controls.; - Populations studied were highly heterogeneous; - 3 natural history studies found that between 1/3 and 2/3 of patients died within 4–5 years.; - Among 6 studies with medical treatments, wide range of mortality estimates across studies. | - Data mostly from prospective cohorts without a control group that indicate BP outcomes as the significantly improved outcome especially among those with higher baseline kidney function; - Mortality was mostly CVD-related; was predicted by lower baseline kidney function, CHF, and influenced by bilateral disease with or without baseline CKD | - Data from retrospective cohort analyses. Some data were poorly reported.; - Major outcomes like long-term mortality, improvements in HTN, and proportion of patients who became dialysis- dependent were similar across studies.
Overall Summary, continued | - The other comparative studies mostly agree with these conclusions, although the studies are heterogeneous in regards to blood pressure outcomes.; - The comparative studies do not adequately address comparative adverse events or the predictive value of baseline variables to determine whether any of these factors would favor one intervention over the other.; - Indirect comparisons between cohort studies of revascularization and of medical treatment confirm the lack of difference in mortality rates between treatments, in resultant kidney function, with the caveat that improvement was reported only in cohort studies of revascularization,; - Across cohort studies, the difference in blood pressure outcomes with either revascularization or medical treatment was uncertain, except that improvement was reported only in cohort studies of revascularization.; - No conclusions could be reached about differences in cardiovascular outcomes or adverse events based on the cohort studies. | - In general patients’ kidney function deteriorated over time, although to different degrees in the different studies.; - All 3 studies of medical treatments for blood pressure control showed that, on average, the various treatment regimens examined were effective for lowering blood pressures in RAS patients to normal ranges. | - There was no difference in blood pressure and kidney outcomes between procedures with and without stent. Studies did not analyze the predictive value of periprocedural interventions

ARAS, atherosclerotic renal artery stenosis; CHF, congestive heart failure; CKD, chronic kidney disease (renal insufficiency); CVD, cardiovascular disease; DM, diabetes mellitus; GFR, glomerular filtration rate; HTN, hypertension; MI, myocardial infarction; N/A, not applicable; NYHA class, New York Heart Association functional class.