# Detailed Mortality Figure

## Detailed Mortality Figure

Figure

Cumulative percent mortality from 6 months to 10 years of followup.