# Peer Reviewers

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report by the peer reviewers.

- Richard Paul Cambria, MD
- Professor of Surgery
- Chief, Division of Vascular and Endovascular Surgery
- Harvard Medical School
- Boston, Massachusetts

- Richard Chapell, PhD
- Outcomes Research Merck & Co., Inc.

- Scott Gilbert, MD
- Assistant Professor of Medicine
- Tufts University School of Medicine
- Director, Kidney and Blood Pressure Center
- Tufts-New England Medical Center
- Boston, Massachusetts

- Linda Humphrey, MD, MPH
- Scientific Resource Center
- Oregon Health and Science University
- Portland, Oregon

- Timothy Murphy, MD
- Professor, Diagnostic Imaging
- Brown University School of Medicine
- Medical Director, Vascular Disease Research Center
- Rhode Island Hospital
- Providence, Rhode Island

- John H. Rundback, MD
- Associate Professor of Clinical Radiology
- College of Physicians and Surgeons of Columbia University
- New York, NewYork
- Robert Safian, MD, FSCAIPeripheral Vascular Disease Committee
- Society for Cardiovascular Angiography and Intervention
- Bethesda, Maryland

- Stephen C. Textor, M.D.
- Division of Nephrology
- Department of Medicine
- Mayo Clinic
- Rochester, Minnesota

- Katherine R. Tuttle, MD
- Director of Research
- The Heart Institute of Spokane
- Spokane, Washington

- I. David Weiner, MD
- Professor of Medicine and Physiology
- Division of Nephrology, Hypertension and Transplantation
- University of Florida College of Medicine
- Chief, Nephrology and Hypertension Section
- Gainesville, Florida

- Kenneth Rosenfield, MD, FSCAI
- Chair, Peripheral Vascular Disease Committee
- Society for Cardiovascular Angiography and Intervention
- Bethesda, Maryland

- Claudia Ruiz-Zacharek, MD
- Division of Nephrology
- University of Texas Medical Branch
- Center for Devices and Radiological Health
- Food and Drug Administration

- R. Eugene Zierler, MD
- Professor of Surgery
- Division of Vascular Surgery
- University of Washington
- Seattle, Washington

- Susan J. Duval, PhD
- Assistant Professor of Epidemiology
- Division of Epidemiology
- University of Minnesota

Drs. Cambria, Gilbert, Rundback, Textor and Tuttle were also members of the EPC’s Technical Expert Panel

Dr. Cambria served as the EPC technical expert consultant. As such his comments were provided on an ongoing basis.