# Excluded Studies

## Excluded Studies

Acher CW, Belzer FO, Grist TM, Turnipseed WD, Hoch JR, Archibald JE. Late renal function in patients undergoing renal revascularization for control of hypertension and/or renal preservation. Cardiovasc Surg 4(5):602–6. 1996

Pre-1993 (Surgery study)

Adams MB, Harris SS, Kauffman HM, Towne JB. Effect of primary renal disease in patients with renovascular insufficiency. J Vasc Surg 1(3):482–6. 1984

N<100 (Surgery study)

Ahmadi R, Schillinger M, Sabeti S, et al. Renal artery PTA and stent implantation: immediate and late clinical and morphological outcome. Wien Klin Wochenschr 114(1–2):21–7. 2002

Retrospective (PTRA study)

Alhadad A, Mattiasson I, Ivancev K, Gottsater A, Lindblad B. Sustained beneficial effects on blood pressure during long time retrospective follow-up after endovascular treatment of renal artery occlusion. J Human Hypertens 18(10):739–44. 2004

Retrospective (PTRA study)

Allie DE, Lirtzman MD, Wyatt CH, et al. Bivalirudin as a foundation anticoagulant in peripheral vascular disease: a safe and feasible alternative for renal and iliac interventions. J Invasive Cardiol 15(6): 334–42. 2003.

Prospective treatment vs retrospective control (Question 3)

Arlart IP, von Dewitz H, Bargon G. Transvenous digital subtraction angiography (DSA) for diagnostic control following percutaneous transluminal angioplasty (PTA) in patients with renovascular surgery. Ann Surg 201(2):219–2. 1985

N<100 (Surgery study)

hypertension. Eur J Radiol 5(2):115–9. 1985

N<30 (PTRA study)

Arlart IP. Digital subtraction angiography (DSA) in renal and renovascular hypertension: diagnostic value and application in follow-up studies after PTA. Uremia Invest 9(2):217–29. 1985

Pre-1993 (Surgery study)

Askari A, Novick AC, Stewart BH, Straffon RA. Surgical treatment of renovascular disease in the solitary kidney: results in 43 cases. J Urol 127(1):20–2. 1982

N<100 (Surgery study)

Baert AL, Wilms G, Amery A, Vermylen J, Suy R. Percutaneous transluminal renal angioplasty: initial results and long-term follow-up in 202 patients. Cardiovasc Intervent Radiol 13(1):22–8. 1990

Pre-1993 (Surgery study)

Bakker J, Goffette PP, Henry M, et al. The Erasme study: a multicenter study on the safety and technical results of the Palmaz stent used for the treatment of atherosclerotic ostial renal artery stenosis. Cardiovasc Intervent Radiol 22(6):468–74. 1999

Post-failed PTRA

Barbalias GA, Liatsikos EN, Siablis D, et al. Virtual endoscopy in renal artery stenosis: an innovative approach for diagnosis and follow-up. J Endourol 18(6):540–3. 2004

N<30 (PTRA study)

Bardram L, Helgstrand U, Bentzen MH, Buchardt Hansen HJ, Engell HC. Late results after surgical treatment of renovascular hypertension. A follow-up study of 122 patients 2–18 years after Baumgartner I, Triller J, Mahler F. Patency of percutaneous transluminal renal angioplasty: a prospective sonographic study. Kidney Int 51(3):798–803. 1997

Prior publication of accepted study

Baus S, Radermacher J, Galanski M, Chavan A. Kissing balloon technique for angioplasty of renal artery bifurcation stenoses. J Vasc Interv Radiol 14(11):1455–9. 2003

Retrospective (PTRA study)

Bax L, Mali WP, van de Ven PJ, Beek FJ, Vos JA, Beutler JJ. Repeated intervention for in-stent restenosis of the renal arteries. J Vasc Interv Radiol 13(12):1219–24. 2002

Retrospective (PTRA study)

Bedoya L, Ziegelbaum M, Vidt DG, Badhwar K, Novick AC, Gifford RW. Baseline renal function and surgical revascularization in atherosclerotic renal arterial disease in the elderly. Cleve Clin J Med 56(4):415–21. 1989

Pre-1993 (Surgery study)

Beebe HG, MacFarlane SD. Antegrade aortorenal bypass graft: a new alternative. Am J Surg 155(5):647–50. 1988

N<100 (Surgery study)

Bell GM, Reid J, Buist TA. Percutaneous transluminal angioplasty improves blood pressure and renal function in renovascular hypertension. Qjm 63(241):393–403. 1987

Retrospective (PTRA study)

Bergrem H, Jervell J, Solheim DM, Flatmark A. Prognostic value of renal vein renin determination in suspected renovascular hypertension. Acta Med Scand Suppl 211(5):387–91. 1982

N<100 (Surgery study)

Beutler JJ, Van Ampting JM, van de Ven PJ, et al. Long-term effects of arterial stenting on kidney function for patients with ostial atherosclerotic renal artery stenosis and renal insufficiency. J Am Soc Nephrol 12(7):1475–81. 2001

>20% had previous plasty

Bhandari S, Wilkinson A, Nicholson A, Farr MJ, Sellars L. Atherosclerotic renovascular disease in the elderly: angioplasty with stenting versus reconstructive surgery. Geriatr Nephrol Urol 7(2):87–94. 1997

Retrospective (PTRA)/N<100 (Surgery)

Binkert CA, Debatin JF, Schneider E, et al. Can MR measurement of renal artery flow and renal volume predict the outcome of percutaneous transluminal renal angioplasty?. Cardiovasc Intervent Radiol 24(4):233–9. 2001

N<30 (PTRA study)

Blaufox MD, Fine EJ, Heller S, et al. Prospective study of simultaneous orthoiodohippurate and diethylenetriaminepentaacetic acid captopril renography. The Einstein/Cornell Collaborative Hypertension Group. J Nucl Medicine 39(3):522–8. 1998

No intervention

Blaufox MD. Cost-effectiveness of nuclear medicine procedures in renovascular hypertension. Semin Nucl Med 19(2):116–21. 1989

Review

Bloch MJ, Trost DA, Whitmer J, Pickering TG, Sos TA, August P. Ostial renal artery stent placement in patients 75 years of age or older. Am J Hypertens 14(10):983–8. 2001

N<30 (PTRA study)

Bloch MJ, Trost DW, Pickering TG, Sos TA, August P. Prevention of recurrent pulmonary edema in patients with bilateral renovascular disease through renal artery stent placement. Am J Hypertens 12(1 Pt 1):1–7. 1999

Retrospective (PTRA study)

Boisclair C, Therasse E, Oliva VL, et al. Treatment of renal angioplasty failure by percutaneous renal artery stenting with Palmaz stents: midterm technical and clinical results. AJR Am J Roentgenol 168(1):245–51. 1997

Post-failed PTRA

Bonelli FS, McKusick MA, Textor SC, et al. Renal artery angioplasty: technical results and clinical outcome in 320 patients. Mayo Clin Proc 70(11):1041–52. 1995

Retrospective (PTRA study)

Bonner G, Lederle RM, Scholze J, Stumpe KO. Therapeutic safety of perindopril in the treatment of mild hypertension with concomitant nephropathy. Arzneimittel-Forschung 43(8):852–5. 1993

Exclusion population

Bush RL, Martin LG, Lin PH, et al. Endovascular revascularization of renal artery stenosis in the solitary functioning kidney. Ann Vasc Surg 15(1):60–6. 2001

N<30 (PTRA study)

Bush RL, Najibi S, MacDonald MJ, et al. Endovascular revascularization of renal artery stenosis: technical and clinical results. J Vasc Surg 33(5):1041–9. 2001

Retrospective (PTRA study)

Cambria RP, Brewster DC, L’Italien GJ, et al. The durability of different reconstructive techniques for atherosclerotic renal artery disease. J Vasc Surg 20(1):76–85. 1994

Pre-1993 (Surgery study)

Cambria RP, Brewster DC, L’Italien GJ, et al. Renal artery reconstruction for the preservation of renal function. J Vasc Surg 24(3):371–80. 1996

Pre-1993 (Surgery study)

Cambria RP, Kaufman JL, Brewster DC, et al. Surgical renal artery reconstruction without contrast arteriography: the role of clinical profiling and magnetic resonance angiography. J Vasc Surg 29(6):1012–21. 1999

N<100 (Surgery study)

Campo A, Boero R, Stratta P, Quarello F. Selective stenting and the course of atherosclerotic renovascular nephropathy. J Nephrol 15(5):525–9. 2002

Retrospective (PTRA study)

Canzanello VJ, Millan VG, Spiegel JE, Ponce PS, Kopelman RI, Madias NE. Percutaneous transluminal renal angioplasty in management of atherosclerotic renovascular hypertension: results in 100 patients. Hypertension 13(2):163–72. 1989

Pre-1993 (Surgery study)

Caps MT, Perissinotto C, Zierler RE, et al. Prospective study of atherosclerotic disease progression in the renal artery. Circulation 98(25):2866–72. 1998

No outcome of interest

Carmichael DJ, Mathias CJ, Snell ME, Peart S. Detection and investigation of renal artery stenosis. Lancet 1(8482):667–70. 1986

Retrospective (PTRA)/N<100 (Surgery)

Chabova V, Schirger A, Stanson AW, McKusick MA, Textor SC. Outcomes of atherosclerotic renal artery stenosis managed without revascularization. Mayo Clin Proc 75(5):437–44. 2000

Pre-1993 (Surgery study)

Chaikof EL, Smith RB, Salam AA, et al. Empirical reconstruction of the renal artery: long-term outcome. J Vasc Surg 24(3):406–14. 1996

N<100 (Surgery study)

Chatterjee SS, Pahari DK, Sharma RK, et al. Long term follow-up of percutaneous transluminal renal angioplasty with special reference to aorto-arteritis. Indian Heart J 47(2):120–4. 1995

Retrospective (PTRA study)

Chatziioannou A, Mourikis D, Agroyannis B, et al. Renal artery stenting for renal insufficiency in solitary kidney in 26 patients. Eur J Vasc Endovascular Surg 23(1):49–54. 2002

Retrospective (PTRA study)

Cianci R, Lavini R, Letizia C, et al. Low-contrast medium doses for ultrasound imaging during renal revascularization by PTA-stenting. J Nephrol 17(4):520–4. 2004

Retrospective (PTRA study)

Cicuto KP, McLean GK, Oleaga JA, Freiman DB, Grossman RA, Ring EJ. Renal artery stenosis: anatomic classification for percutaneous transluminal angioplasty. AJR Am J Roentgenol 137(3):599–601. 1981

Retrospective (PTRA study)

Cioni R, Vignali C, Petruzzi P, et al. Renal artery stenting in patients with a solitary functioning kidney. Cardiovasc Intervent Radiol 24(6):372–7. 2001

Retrospective (PTRA study)

Cognet F, Garcier JM, Dranssart M, et al. Percutaneous transluminal renal angioplasty in atheroma with renal failure: long-term outcomes in 99 patients. Eur Radiol 11(12):2524–30. 2001

Retrospective (PTRA study)

Colapinto RF, Stronell RD, Harries-Jones EP, et al. Percutaneous transluminal dilatation of the renal artery: follow-up studies on renovascular hypertension. AJR Am J Roentgenol 139(4):727–32. 1982

Pre-1993 (Surgery study)

Conlon PJ, Athirakul K, Kovalik E, et al. Survival in renal vascular disease. J Am Soc Nephrol 9(2):252–6. 1998

Pre-1993 (Surgery study)

Connolly JO, Higgins RM, Walters HL, et al. Presentation, clinical features and outcome in different patterns of atherosclerotic renovascular disease. Qjm 87(7):413–21. 1994

Retrospective (PTRA study)

Cormier JM, Fichelle JM, Laurian C, Gigou F, Artru B, Ricco JB. Renal artery revascularization with polytetrafluoroethylene bypass graft. Ann Vasc Surg 4(5):471–8. 1990

N<100 (Surgery study)

Crinnion JN, Gough MJ. Bilaterial renal artery atherosclerosis--the results of surgical treatment. Eur J Vasc Endovascular Surg 11(3):353–8. 1996

>50% had aortic reconstruction

Crowley JJ, Santos RM, Peter RH, et al. Progression of renal artery stenosis in patients undergoing cardiac catheterization. Am Heart J 136(5):913–8. 1998

No outcome of interest

Dal Canton A, Russo D, Iaccarino V, Caputo A, D’Anna F, Andreucci VE. Percutaneous angioplasty for treatment of renovascular hypertension. Proc Eur Dial Transplant Assoc 20:582–6. 1983

N<30 (PTRA study)

de Fraissinette B, Garcier JM, Dieu V, et al. Percutaneous transluminal angioplasty of dysplastic stenoses of the renal artery: results on 70 adults. Cardiovasc Intervent Radiol 26(1):46–51. 2003

Retrospective (PTRA study)

Dean RH, Kieffer RW, Smith BM, et al. Renovascular hypertension: anatomic and renal function changes during drug therapy. Archives Surg 116(11):1408–15. 1981

Pre-1993 (Surgery study)

Dean RH, Krueger TC, Whiteneck JM, et al. Operative management of renovascular hypertension. Results after a follow-up of fifteen to twenty-three years. J Vasc Surg 1(1):234–42. 1984

N<100 (Surgery study)

Dean RH, Tribble RW, Hansen KJ, O’Neil E, Craven TE, Redding JF. Evolution of renal insufficiency in ischemic nephropathy. Ann Surg 213(5):446–55. 1991

N<100 (Surgery study)

Dean RH. Late results of aortorenal bypass. Urol Clin North Am 11(3):425–34. 1984

Pre-1993 (Surgery study)

Denolle T, Chatellier G, Julien J, Battaglia C, Luo P, Plouin PF. Left ventricular mass and geometry before and after etiologic treatment in renovascular hypertension, aldosterone-producing adenoma, and pheochromocytoma. Am J Hypertens 6(11 Pt 1):907–13. 1993

Retrospective (PTRA)/N<100 (Surgery)

Desai TR, Meyerson SL, McKinsey JF, Schwartz LB, Bassiouny HS, Gewertz BL. Angioplasty does not affect subsequent operative renal artery revascularization. Surgery 128(4):717–25. 2000

N<100 (Surgery study)

Dondi M, Fanti S, De Fabritiis A, et al. Prognostic value of captopril renal scintigraphy in renovascular hypertension. J Nucl Medicine 33(11):2040–4. 1992

Pre-1993 (Surgery study)

Donohoe P, de Takats D, Bishop N, et al. A four-year audit of interventional treatment for atheromatous renal artery stenosis. Contrib Nephrol 119:78–82. 1996

Retrospective (PTRA)/N<100 (Surgery)

Dorros G, Prince C, Mathiak L. Stenting of a renal artery stenosis achieves better relief of the obstructive lesion than balloon angioplasty. Catheter Cardiovasc Diagn 29(3):191–8. 1993

N<30 (PTRA study)

Eldrup-Jorgensen J, Harvey HR, Sampson LN, Amberson SM, Bredenberg CE. Should percutaneous transluminal renal artery angioplasty be applied to ostial renal artery atherosclerosis?. J Vasc Surg 21(6):909–14. 1995

Retrospective (PTRA study)

England WL, Roberts SD, Grim CE. Surgery or angioplasty for cost-effective renal revascularization?. Med Dec Making 7(2):84–91. 1987

Retrospective (PTRA)/N<100 (Surgery)

Erbsloh-Moller B, Dumas A, Roth D, Sfakianakis GN, Bourgoignie JJ. Furosemide-131I-hippuran renography after angiotensin-converting enzyme inhibition for the diagnosis of renovascular hypertension. Am J Med 90(1):23–9. 1991

N<30 (PTRA study)

Erdoes LS, Berman SS, Hunter GC, Mills JL. Comparative analysis of percutaneous transluminal angioplasty and operation for renal revascularization. Am J Kidney Dis 27(4):496–503. 1996

Retrospective (PTRA)/N<100 (Surgery)

Esper IE, Chajari M, Fonroget J, et al. Steady-state captopril renography: continuous monitoring of the captopril-induced increase in 99mTc-MAG3 mean parenchymal transit time in renovascular hypertension. Eur J Nucl Med 24(7):739–44. 1997

N<30 (PTRA study)

Fergany A, Kolettis P, Novick AC. The contemporary role of extra-anatomical surgical renal revascularization in patients with atherosclerotic renal artery disease. J Urol 153(6):1798–801. 1995

Pre-1993 (Surgery study)

Fiala LA, Jackson MR, Gillespie DL, O’Donnell SD, Lukens M, Gorman P. Primary stenting of atherosclerotic renal artery ostial stenosis. Ann Vasc Surg 12(2):128–33. 1998

Retrospective (PTRA study)

Fichelle JM, Colacchio G, Farkas JC, et al. Renal revascularization in high-risk patients: the role of iliac renal bypass. Ann Vasc Surg 6(5):403–7. 1992

N<100 (Surgery study)

Fiorani P, Faraglia V, Aissa N, et al. Late results of reconstructive surgery for renovascular hypertension. Int Angiol 8(2):81–91. 1989

Pre-1993 (Surgery study)

Flechner S, Novick AC, Vidt D, Buonocore E, Meaney T. The use of percutaneous transluminal angioplasty for renal artery stenosis in patients with generalized atherosclerosis. J Urol 127(6):1072–5. 1982

Retrospective (PTRA study)

Fletcher JP, Simmons K, Little JM. Percutaneous transluminal angioplasty: experience at Westmead Centre. Australas Radiol 29(2):158–62. 1985

Retrospective (PTRA study)

Fommei E, Mezzasalma L, Ghione S, et al. European Captopril Radionuclide Test Multicenter Study. Preliminary results. Inspective renographic analysis. The European Captopril Radionuclide Test Multicenter Study Group. Am J Hypertens 4(12 Pt 2):690S–697S. 1991

Pre-1993 (Surgery study)

Fouad FM, Gifford RW, Fighali S, et al. Predictive value of angiotensin II antagonists in renovascular hypertension. JAMA 249(3):368–73. 1983

N<100 (Surgery study)

Fowl RJ, Hollier LH, Bernatz PE, Pairolero PC, Vogt PA, Cherry KJ. Repeat revascularization versus nephrectomy in the treatment of recurrent renovascular hypertension. Surg Gynecol Obstet 162(1):37–42. 1986

N<100 (Surgery study)

Frauchiger B, Zierler R, Bergelin RO, Isaacson JA, Strandness DE. Prognostic significance of intrarenal resistance indices in patients with renal artery interventions: a preliminary duplex sonographic study. Cardiovasc Surg 4(3):324–30. 1996

N<30 (PTRA study)

Fry RE, Fry WJ. Supraceliac aortorenal bypass with saphenous vein for renovascular hypertension. Surg Gynecol Obstet 168(2):180–2. 1989

Pre-1993 (Surgery study)

Galli M, Tarantino F, Mameli S, et al. Transradial approach for renal percutaneous transluminal angioplasty and stenting: a feasibility pilot study. J Invasive Cardiol 14(7):386–90. 2002

N<30 (PTRA study)

Geroulakos G, Wright JG, Tober JC, Anderson L, Smead WL. Use of the splenic and hepatic artery for renal revascularization in patients with atherosclerotic renal artery disease. Ann Vasc Surg 11(1):85–9. 1997

N<100 (Surgery study)

Geyskes GG, de Bruyn AJ. Captopril renography and the effect of percutaneous transluminal angioplasty on blood pressure in 94 patients with renal artery stenosis. Am J Hypertens 4(12 Pt 2):685S–689S. 1991

Pre-1993 (Surgery study)

Geyskes GG, Puylaert CB, Oei HY, Mees EJ. Follow up study of 70 patients with renal artery stenosis treated by percutaneous transluminal dilatation. BMJ 287(6388):333–6. 1983

Retrospective (PTRA study)

Gill IS, Novick AC, Hodge EE. Extra-anatomic renal revascularization in patients with renal artery stenosis and abdominal aortic occlusion. Urology 42(6):630–4. 1993

N<100 (Surgery study)

Giroux MF, Soulez G, Therasse E, et al. Percutaneous revascularization of the renal arteries: predictors of outcome. J Vasc Interv Radiol 11(6):713–20. 2000

Retrospective (PTRA study)

Giulini SM, Bonardelli S, Cangiotti L, et al. Surgery for obstructive lesions of the main trunk of the renal artery. A review of the literature and personal experience of 41 operated patients. J Cardiovasc Surg 36(4):329–36. 1995

N<100 (Surgery study)

Greminger P, Luscher TF, Zuber J, et al. Surgery, transluminal dilatation and medical therapy in the management of renovascular hypertension. Nephron 44 Suppl 1:36–9. 1986

<50% with ARAS

Greminger P, Vetter H, Steurer J, Siegenthaler W, Vetter W. Captopril and kidney function in renovascular and essential hypertension. Nephron 44 Suppl 1:91–5. 1986

N<10 (Medical study)

Grim CE, Luft FC, Yune HY, Klatte EC, Weinberger MH. Percutaneous transluminal dilatation in the treatment of renal vascular hypertension. Ann Intern Med 95(4):439–42. 1981

N<30 (PTRA study)

Grim CE, Yune HY, Donohue JP, Weinberger MH, Dilley R, Klatte EC. Renal vascular hypertension. Surgery vs. dilation. Nephron 44 Suppl 1:96–100. 1986

Retrospective (PTRA)/N<100 (Surgery)

Grim CE, Yune HY, Weinberger MH, Donohue JP. Percutaneous transluminal dilatation or surgery in the management of renal vascular hypertension?. Clin Sci 61 Suppl 7:485s–486s. 1981

N<30 (PTRA study)

Gruenewald SM, Collins LT, Antico VF, Farlow DC, Fawdry RM. Can quantitative renography predict the outcome of treatment of atherosclerotic renal artery stenosis?. J Nucl Medicine 30(12):1946–54. 1989

Retrospective (PTRA)/N<100 (Surgery)

Grutzmacher P, Bussmann WD, Meyer TH, et al. Non-operative revascularisation of renal artery occlusion by transluminal angioplasty. Nephrol Dial Transplant 3(2):130–7. 1988

N<30 (PTRA study)

Guerrero M, Syed A, Khosla S. Survival following renal artery stent revascularization: four-year follow-up. J Invasive Cardiol 16(7):368–71. 2004

Retrospective (PTRA study)

Haddad M, Barral X, Boissier C, Bouilloc X, Beraud AM. Extracorporeal repair of renal artery branch lesions. Eur J Vasc Surg 3(5):435–41. 1989

N<100 (Surgery study)

Hagino RT, Valentine RJ, Clagett GP. Supraceliac aortorenal bypass. J Vasc Surg 26(3):482–9. 1997

N<100 (Surgery study)

Hagspiel KD, Stone JR, Leung DA. Renal angioplasty and stent placement with distal protection: preliminary experience with the FilterWire EX. J Vasc Interv Radiol 16(1):125–31. 2005

Retrospective (PTRA study)

Halimi JM, Ribstein J, Du CG, Ennouchi JM, Mimran A. Albuminuria predicts renal functional outcome after intervention in atheromatous renovascular disease. J Hypertens 13(11):1335–42. 1995

N<30 (PTRA study)

Hallett JW, Fowl R, O’Brien PC, et al. Renovascular operations in patients with chronic renal insufficiency: do the benefits justify the risks?. J Vasc Surg 5(4):622–7. 1987

N<100 (Surgery study)

Hallett JW, Textor SC, Kos PB, et al. Advanced renovascular hypertension and renal insufficiency: trends in medical comorbidity and surgical approach from 1970 to 1993. J Vasc Surg 21(5):750–9. 1995

Pre-1993 (Surgery study)

Hansen KJ, Deitch JS, Oskin TC, Ligush J, Craven TE, Dean RH. Renal artery repair: consequence of operative failures. Ann Surg 227(5):678–89. 1998

Post-failed PTRA

Hansen KJ, Ditesheim JA, Metropol SH, et al. Management of renovascular hypertension in the elderly population. J Vasc Surg 10(3):266–73. 1989

N<100 (Surgery study)

Hansen KJ, Lundberg AH, Benjamin ME, et al. Is renal revascularization in diabetic patients worthwhile?. J Vasc Surg 24(3):383–92. 1996

N<100 (Surgery study)

Hansen KJ, O’Neil EA, Reavis SW, Craven TE, Plonk GW, Dean RH. Intraoperative duplex sonography during renal artery reconstruction. J Vasc Surg 14(3):364–74. 1991

N<100 (Surgery study)

Hansen KJ, Starr SM, Sands RE, Burkart JM, Plonk GW, Dean RH. Contemporary surgical management of renovascular disease. J Vasc Surg 16(3):319–30. 1992

Pre-1993 (Surgery study)

Hansen KJ, Thomason RB, Craven TE, et al. Surgical management of dialysis-dependent ischemic nephropathy. J Vasc Surg 21(2):197–209. 1995

N<100 (Surgery study)

Hansson BG, Bergentz SE, Dymling JF, Hedeland H, Hokfelt B. Pre- and postoperative studies in 72 hypertensive patients with renal artery stenosis, with special reference to renin activity and aldosterone. Acta Med Scand Suppl 210(4):249–55. 1981

N<100 (Surgery study)

Hanzel G, Balon H, Wong O, Soffer D, Lee DT, Safian RD. Prospective evaluation of aggressive medical therapy for atherosclerotic renal artery stenosis, with renal artery stenting reserved for previously injured heart, brain, or kidney. Am J Cardiol 96(9):1322–7. 2005

N<30 (PTRA study; accepted for medical cohort)

Harward TR, Poindexter B, Huber TS, Carlton LM, Flynn TC, Seeger JM. Selection of patients for renal artery repair using captopril testing. Am J Surg 170(2):183–7. 1995

Retrospective (PTRA)/N<100 (Surgery)

Harward TR, Smith S, Hawkins IF, Seeger JM. Follow-up evaluation after renal artery bypass surgery with use of carbon dioxide arteriography and color-flow duplex scanning. J Vasc Surg 18(1):23–30. 1993

N<100 (Surgery study)

Hasbak P, Jensen LT, Ibsen H, East Danish Study Group on Renovascular Hypertension. Hypertension and renovascular disease: follow-up on 100 renal vein renin samplings. J Human Hypertens 16(4):275–80. 2002

N<30 (PTRA study)

Helin KH, Lepantalo M, Edgren J, Liewendahl K, Tikkanen T, Tikkanen I. Predicting the outcome of invasive treatment of renal artery disease. J Intern Medicine 247(1):105–10. 2000

N<30 (PTRA study)

Helin KH, Tikkanen I, von Knorring JE, et al. Screening for renovascular hypertension in a population with relatively low prevalence. J Hypertens 16(10):1523–9. 1998

N<30 (PTRA study)

Hennequin LM, Joffre FG, Rousseau HP, et al. Renal artery stent placement: long-term results with the Wallstent endoprosthesis. Radiology. 1994

N<30 (PTRA study)

Henry M, Amor M, Henry I, et al. Stent placement in the renal artery: three-year experience with the Palmaz stent. J Vasc Interv Radiol 7(3):343–50. 1996

Retrospective (PTRA study)

Henry M, Amor M, Henry I, et al. Stents in the treatment of renal artery stenosis: long-term follow-up. J Endovascular Surg 6(1):42–51. 1999

Post-failed PTRA

Henry M, Klonaris C, Henry I, et al. Protected renal stenting with the PercuSurge GuardWire device: a pilot study. J Endovascular Ther 8(3):227–37. 2001

N<30 (PTRA study)

Hodsman GP, Brown JJ, Cumming AM, et al. Enalapril (MK421) in the treatment of hypertension with renal artery stenosis. J Hypertens Suppl 1(1):109–17. 1983

<6 mo (nd AE)

Hodsman GP, Brown JJ, Cumming AM, et al. Enalapril in treatment of hypertension with renal artery stenosis. Changes in blood pressure, renin, angiotensin I and II, renal function, and body composition. Am J Med 77(2A):52–60. 1984

<6 mo (nd AE)

Hoffman O, Carreres T, Sapoval MR, et al. Ostial renal artery stenosis angioplasty: immediate and mid-term angiographic and clinical results. J Vasc Interv Radiol 9(1 Pt 1):65–73. 1998

Retrospective (PTRA study)

Holden A, Hill A. Renal angioplasty and stenting with distal protection of the main renal artery in ischemic nephropathy: early experience. J Vasc Surg 38(5):962–8. 2003

Retrospective (PTRA study)

Hudspeth DA, Hansen KJ, Reavis SW, Starr SM, Appel RG, Dean RH. Renal duplex sonography after treatment of renovascular disease. J Vasc Surg 18(3):381–8. 1993

Pre-1993 (Surgery study)

Hupp T, Clorius JH, Allenberg JR. Renovascular hypertension: predicting surgical cure with exercise renography. J Vasc Surg 14(2):200–7. 1991

Pre-1993 (Surgery study)

Ilkay E, Gunal IA, Yavuzkir M, et al. Effect of renal artery stenting on renal function in patients with ischemic nephropathy. Jpn Heart J 45(4):637–45. 2004

N<30 (PTRA study)

Isles C, Main J, O’Connell J, et al. Survival associated with renovascular disease in Glasgow and Newcastle: a collaborative study. Scott Med J 35(3):70–3. 1990

Pre-1993 (Surgery study)

Ivanovic V, McKusick MA, Johnson CM, et al. Renal artery stent placement: complications at a single tertiary care center. J Vasc Interv Radiol 14(2 Pt 1):217–25. 2003

Retrospective (PTRA study)

Jenni R, Vieli A, Luscher TF, Schneider E, Vetter W, Anliker M. Combined two-dimensional ultrasound Doppler technique. New possibilities for the screening of renovascular and parenchymatous hypertension?. Nephron 44 Suppl 1:2–4. 1986

Retrospective (PTRA study)

Jensen G, Moonen M, Aurell M, Granerus G, Volkmann R. Reliability of ACE inhibitor-enhanced 99Tcm-DTPA gamma camera renography in the detection of renovascular hypertension. Nucl Med Commun 14(3): 169–75. 1993

N<30 (PTRA study)

Jensen G, Zachrisson BF, Delin K, Volkmann R, Aurell M. Treatment of renovascular hypertension: one year results of renal angioplasty. Kidney Int 48(6):1936–45. 1995

Retrospective (PTRA study)

Joffre F, Rousseau H, Bernadet P, et al. Midterm results of renal artery stenting. Cardiovasc Intervent Radiol 15(5):313–8. 1992

N<30 (PTRA study)

Julien J, Jeunemaitre X, Raynaud A, et al. Influence of age on the outcome of percutaneous angioplasty in atheromatous renovascular disease. J Hypertens Suppl 7(6):S188–9. 1989

Retrospective (PTRA study)

Kadir S, Russell RP, Kaufman SL, et al. Renal artery angioplasty. Technical considerations and results. Rofo Fortschr Geb Rontgenstr Nuklearmed 141(4):378–83. 1984

N<30 (PTRA study)

Kaplan-Pavlovcic S, Nadja C. Captopril renography and duplex Doppler sonography in the diagnosis of renovascular hypertension. Nephrol Dial Transplant 13(2):313–7. 1998

N<30 (PTRA study)

Karagiannis A, Douma S, Voyiatzis K, et al. Percutaneous transluminal renal angioplasty in patients with renovascular hypertension: long-term results. Hypertens Res 18(1):27–31. 1995

Pre-1993 (Surgery study)

Kaylor WM, Novick AC, Ziegelbaum M, Vidt DG. Reversal of end stage renal failure with surgical revascularization in patients with atherosclerotic renal artery occlusion. J Urol 141(3):486–8. 1989

N<100 (Surgery study)

Keith TA. Renovascular hypertension in black patients. Hypertension 4(3):438–43. 1982

Pre-1993 (Surgery study)

Kent KC, Salvatierra O, Reilly LM, Ehrenfeld WK, Goldstone J, Stoney RJ. Evolving strategies for the repair of complex renovascular lesions. Ann Surg 206(3):272–8. 1987

N<100 (Surgery study)

Khilnani NM, Trost D, Jagust MB, Sos TA. Multiple-side-hole catheter technique for selective over-the-wire completion angiography following renal angioplasty. J Vasc Interv Radiol 5(2):387–9. 1994

Retrospective (PTRA study)

Khosla S, White CJ, Collins TJ, Jenkins JS, Shaw D, Ramee SR. Effects of renal artery stent implantation in patients with renovascular hypertension presenting with unstable angina or congestive heart failure. Am J Cardiol 80(3):363–6. 1997

N<30 (PTRA study)

Kim PK, Spriggs DW, Rutecki GW, Reaven RE, Blend D, Whittier FC. Transluminal angioplasty in patients with bilateral renal artery stenosis or renal artery stenosis in a solitary functioning kidney. AJR Am J Roentgenol 153(6):1305–8. 1989

Retrospective (PTRA study)

Kjellbo H, Lund N, Bergentz SE, Hood B. Renal artery stenosis and hypertension. II. Mortality in operated patients compared with the mortality in individually matched medically treated patients with cryptogenetic hypertension. Scand J Urol Nephrol 4(1):43–7. 1970

Pre-1993 (Surgery study)

Klinge J, Mali WP, Puijlaert CB, Geyskes GG, Becking WB, Feldberg MA. Percutaneous transluminal renal angioplasty: initial and long-term results. Radiology 171(2):501–6. 1989

Retrospective (PTRA study)

Klow NE, Paulsen D, Vatne K, Rokstad B, Lien B, Fauchald P. Percutaneous transluminal renal artery angioplasty using the coaxial technique. Ten years of experience from 591 procedures in 419 patients. Acta Radiol 39(6):594–603. 1998

Retrospective (PTRA study)

Korsakas S, Mohaupt MG, Dinkel HP, et al. Delay of dialysis in end-stage renal failure: prospective study on percutaneous renal artery interventions. Kidney Int 65(1):251–8. 2004

N<30 (PTRA study)

Koyanagi T, Nonomura K, Takeuchi I, Watarai Y, Seki T, Kakizaki H. Surgery for renovascular diseases: a single-center experience in revascularizing renal artery stenosis and aneurysm. Urol Int 68(1):24–31. 2002

N<100 (Surgery study)

Kremer Hovinga TK, de Jong PE, de Zeeuw D, Donker AJ, Schuur KH, van der Hem GK. Restenosis prevalence and long-term effects on renal function after percutaneous transluminal renal angioplasty. Nephron 44 Suppl 1:64–7. 1986

Retrospective (PTRA study)

Krishnamurthi V, Novick AC, Myles JL. Atheroembolic renal disease: effect on morbidity and survival after revascularization for atherosclerotic renal artery stenosis. J Urol 161(4):1093–6. 1999

N<100 (Surgery study)

Kuhlmann U, Greminger P, Gruntzig A, et al. Long-term experience in percutaneous transluminal dilatation of renal artery stenosis. Am J Med 79(6):692–8. 1985

Pre-1993 (Surgery study)

Kuhlmann U, Vetter W, Furrer J, Lutolf U, Siegenthaler W, Gruntzig A. Renovascular hypertension: treatment by percutaneous transluminal dilatation. Ann Intern Med 92(1):1–6. 1980

Retrospective (PTRA study)

Kuhn FP, Kutkuhn B, Torsello G, Modder U. Renal artery stenosis: preliminary results of treatment with the Strecker stent. Radiology 180(2):367–72. 1991

Retrospective (PTRA study)

Kumagai H, Suzuki H, Matsukawa S, Ryuzaki M, Saruta T. Captopril therapy following percutaneous transluminal angioplasty for bilateral renal artery stenosis. Arch Intern Med 149(9):1973–6. 1989

N<30 (PTRA study)

Kvist S, Mulvany MJ. Reduced medication and normalization of vascular structure, but continued hypertension in renovascular patients after revascularization. Cardiovas Res 52(1):136–42. 2001

Retrospective (PTRA)/N<100 (Surgery)

La Batide-Alanore A, Azizi M, Froissart M, Raynaud A, Plouin PF. Split renal function outcome after renal angioplasty in patients with unilateral renal artery stenosis. J Am Soc Nephrol 12(6):1235–41. 2001

N<30 (PTRA study)

Laasonen L, Edgren J, Forslund T, Eklund B. Renal transplant artery stenosis and percutaneous transluminal angioplasty. Acta Radiol 26(5):609–13. 1985

Exclusion population

Lagneau P, Michel JB. Surgical management and results of renal artery revascularization. Int Angiol 4(3):329–33. 1985

Pre-1993 (Surgery study)

Lamawansa MD, Bell R, House AK. Short-term and long-term outcome following renovascular reconstruction. Cardiovasc Surg 3(1):50–5. 1995

N<100 (Surgery study)

Lawrie GM, Morris GC, DeBakey ME. Long-term results of treatment of the totally occluded renal artery in forty patients with renovascular hypertension. Surgery 88(6):753–9. 1980

Pre-1993 (Surgery study)

Lawrie GM, Morris GC, Glaeser DH, DeBakey ME. Renovascular reconstruction: factors affecting long-term prognosis in 919 patients followed up to 31 years. Am J Cardiol 63(15):1085–92. 1989

Pre-1993 (Surgery study)

Lawrie GM, Morris GC, Soussou ID, et al. Late results of reconstructive surgery for renovascular disease. Ann Surg 191(5):528–33. 1980

Pre-1993 (Surgery study)

Leertouwer TC, Derkx FH, Pattynama PM, Deinum J, van Dijk LC, Schalekamp MA. Functional effects of renal artery stent placement on treated and contralateral kidneys. Kidney Int 62(2):574–9. 2002

Retrospective (PTRA study)

Lewis BE, Leya FS, Johnson SA, et al. Improved hemodynamic, angiographic and functional results after renal artery stenting. J Invasive Cardiol 6(4):136–40. 1994

N<30 (PTRA study)

Li JJ, Fang CH, Jiang H, et al. Increased C-reactive protein level after renal stent implantation in patients with atherosclerotic renal stenosis. Angiology 55(5):479–84. 2004

No outcome of interest

Losinno F, Zuccala A, Busato F, Zucchelli P. Renal artery angioplasty for renovascular hypertension and preservation of renal function: long-term angiographic and clinical follow-up. AJR Am J Roentgenol 162(4):853–7. 1994

Retrospective (PTRA study)

Lovaria A, Nicolini A, Meregaglia D, et al. Interventional radiology in the treatment of renal artery stenosis. Ann Urol (Paris) 33(3):146–55. 1999

Retrospective (PTRA study)

Lyons D, Fowler G, Petrie JC, Webster J. The haemodynamic effects of GR 32191, a thromboxane A2 receptor antagonist, in patients with renal artery stenosis and hypertension. Br J Clin Pharmacol 36(3):271–3. 1993

Single dose

Mackrell PJ, Langan EM, Sullivan TM, et al. Management of renal artery stenosis: effects of a shift from surgical to percutaneous therapy on indications and outcomes. Ann Vasc Surg 17(1):54–9. 2003

Retrospective (PTRA)/N<100 (Surgery)

MacLeod M, Taylor AD, Baxter G, et al. Renal artery stenosis managed by Palmaz stent insertion: technical and clinical outcome. J Hypertens 13(12 Pt 2):1791–5. 1995

N<30 (PTRA study)

Madias NE, Kwon OJ, Millan VG. Percutaneous transluminal renal angioplasty. A potentially effective treatment for preservation of renal function. Arch Intern Med 142(4):693–7. 1982

N<30 (PTRA study)

Mahler F, Probst P, Weidmann P, Krneta A. Transluminal dilatation of renal artery stenoses due to atherosclerosis and fibromuscular dysplasia: early results and follow-up of twelve consecutive cases. Ann Radiol (Paris) 24(5):355–6. 1981

Retrospective (PTRA study)

Marekovic Z, Mokos I, Krhen I, Goreta NR, Roncevic T. Long-term outcome after surgical kidney revascularization for fibromuscular dysplasia and atherosclerotic renal artery stenosis. J Urol 171(3):1043–5. 2004

N<100 (Surgery study)

Marshall FI, Hagen S, Mahaffy RG, et al. Percutaneous transluminal angioplasty for atheromatous renal artery stenosis--blood pressure response and discriminant analysis of outcome predictors. Qjm 75(277):483–9. 1990

Retrospective (PTRA study)

Martin LG, Casarella WJ, Alspaugh JP, Chuang VP. Renal artery angioplasty: increased technical success and decreased complications in the second 100 patients. Radiology 159(3):631–4. 1986

Retrospective (PTRA study)

Martin LG, Casarella WJ, Gaylord GM. Azotemia caused by renal artery stenosis: treatment by percutaneous angioplasty. AJR Am J Roentgenol 150(4):839–44. 1988

Retrospective (PTRA study)

Martin LG, Cork RD, Kaufman SL. Long-term results of angioplasty in 110 patients with renal artery stenosis. J Vasc Interv Radiol 3(4):619–26. 1992

Pre-1993 (Surgery study)

Martinez-Amenos A, Rama H, Sarrias X, Galceran J, Alsina J, Montanya X. Percutaneous transluminal angioplasty in the treatment of renovascular hypertension. J Human Hypertens 5(2):97–100. 1991

Retrospective (PTRA study)

Matalon TA, Thompson MJ, Patel SK, Brunner MC, Merkel FK, Jensik SC. Percutaneous transluminal angioplasty for transplant renal artery stenosis. J Vasc Interv Radiol 3(1):55–8. 1992

Exclusion population

Mathias CJ, Wilkinson AH, Pike FA, Sever PS, Peart WS. Clonidine in unilateral renal artery stenosis and unilateral renal parenchymal disease--similar antihypertensive but different renin suppressive effects. J Hypertens Suppl 1(2):123–5. 1983

Single dose

May J, Sheil R, Harris J, Horvath J. Failure of patent aorto-renal grafts to cure hypertension in renin positive patients. J Cardiovasc Surg 28(5):535–7. 1987

N<100 (Surgery study)

McCready RA, Daugherty ME, Nighbert EJ, Hyde GL, Freedman AM, Ernst CB. Renal revascularization in patients with a single functioning ischemic kidney. J Vasc Surg 6(2):185–90. 1987

N<100 (Surgery study)

McDonald DN, Smith DC, Maloney MD. Percutaneous transluminal renal angioplasty in the patient with a solitary functioning kidney. AJR Am J Roentgenol 151(5):1041–3. 1988

Retrospective (PTRA study)

Mestres CA, Campistol JM, Ninot S, et al. Improvement of renal function in azotaemic hypertensive patients after surgical revascularization. Br J Surg 75(6):578–80. 1988

N<100 (Surgery study)

Milot A, Lambert R, Lebel M, Cusson JR, Larochelle P. Prostaglandins and renal function in hypertensive patients with unilateral renal artery stenosis and patients with essential hypertension. J Hypertens 14(6):765–71. 1996

No intervention

Miranda JF, Perez MC, Plavnik F, Francisco JJ, Burihan E. Percutaneous transluminal angioplasty in the treatment of renovascular hypertension: sequential prospective study. Sao Paulo Med J 116(1):1613–7. 1998

Retrospective (PTRA study)

Miyamori I, Yasuhara S, Matsubara T, Takasaki H, Takeda R. Comparative effects of captopril and nifedipine on split renal function in renovascular hypertension. Am J Hypertens 1(4 Pt 1):359–63. 1988

Case Report

Moncure AC, Brewster DC, Darling RC, Atnip RG, Newton WD, Abbott WM. Use of the splenic and hepatic arteries for renal revascularization. J Vasc Surg 3(2):196–203. 1986

N<100 (Surgery study)

Morellato C, Bergelin RO, Cantwell-Gab K, et al. Clinical and duplex ultrasound follow-up after balloon angioplasty for atherosclerotic renal artery stenosis. Vasc Surg 35(2):85–93. 2001

Retrospective (PTRA study)

Morganti A, Quorso P, Ferraris P, et al. Time-course of the changes in blood pressure and in plasma renin activity during the first week after dilation of renal artery stenosis. J Hypertens Suppl 7(6):S186–7. 1989

N<30 (PTRA study)

Morganti A, Quorso P, Ferraris P, et al. Initial versus long-term results of percutaneous transluminal renal angioplasty in patients with renovascular hypertension. J Hypertens Suppl 9(6):S238–9. 1991

N<30 (PTRA study)

Morin JE, Hutchinson TA, Lisbona R. Long-term prognosis of surgical treatment of renovascular hypertension: a fifteen-year experience. J Vasc Surg 3(3):545–9. 1986

N<100 (Surgery study)

Mounier-Vehier C, Haulon S, Lions C, et al. Renal atrophy in atherosclerotic renovascular disease: gradual changes 6 months after successful angioplasty. J Endovascular Ther 9(6):863–72. 2002

N<30 (PTRA study)

Muray S, Martin M, Amoedo ML, et al. Rapid decline in renal function reflects reversibility and predicts the outcome after angioplasty in renal artery stenosis. Am J Kidney Dis 39(1):60–6. 2002

Retrospective (PTRA study)

Nahman NS, Maniam P, Hernandez RA, et al. Renal artery pressure gradients in patients with angiographic evidence of atherosclerotic renal artery stenosis. Am J Kidney Dis 24(4):695–9. 1994

No outcome of interest

Neymark E, LaBerge JM, Hirose R, et al. Arteriographic detection of renovascular disease in potential renal donors: incidence and effect on donor surgery. Radiology 214(3):755–60. 2000

No intervention

Nolan BW, Schermerhorn ML, Powell RJ, et al. Restenosis in gold-coated renal artery stents. J Vasc Surg 42(1):40–6. 2005

Retrospective (PTRA study)

Nolan BW, Schermerhorn ML, Rowell E, et al. Outcomes of renal artery angioplasty and stenting using low-profile systems. J Vasc Surg 41(1):46–52. 2005

Retrospective (PTRA study)

Novick AC, Ziegelbaum M, Vidt DG, Gifford RW, Pohl MA, Goormastic M. Trends in surgical revascularization for renal artery disease. Ten years’ experience. JAMA 257(4):498–501. 1987

Pre-1993 (Surgery study)

O’Donovan RM, Gutierrez OH, Izzo JL. Preservation of renal function by percutaneous renal angioplasty in high-risk elderly patients: short-term outcome. Nephron 60(2):187–92. 1992

Retrospective (PTRA study)

Oertle M, Do DD, Baumgartner I, Triller J, Mahler F. Discrepancy of clinical and angiographic results in the follow-up of percutaneous transluminal renal angioplasty (PTRA). Vasa 27(3):154–7. 1998

Retrospective (PTRA study)

Oskin TC, Hansen KJ, Deitch JS, Craven TE, Dean RH. Chronic renal artery occlusion: nephrectomy versus revascularization. J Vasc Surg 29(1):140–9. 1999

Complete occlusion

Parildar M, Parildar Z, Oran I, Kabaroglu C, Memis A, Bayindir O. Nitric oxide and oxidative stress in atherosclerotic renovascular hypertension: effect of endovascular treatment. J Vasc Interv Radiol 14(7):887–92. 2003

N<30 (PTRA study)

Parildar Z, Gulter C, Parildar M, Oran I, Erdener D, Memis A. Effect of endovascular treatment on nitric oxide and renal function in Takayasu’s arteritis with renovascular hypertension. Kidney Blood Press Res 25(2):91–6. 2002

Exclusion population

Park JS, Park JH, Kang JY, et al. Hyperfibrinogenemia is an independent risk factor for atherosclerotic renal artery stenosis. Am J Nephrol 19(6):649–54. 1999

No intervention

Park S, Jung JH, Seo HS, et al. The prevalence and clinical predictors of atherosclerotic renal artery stenosis in patients undergoing coronary angiography. Heart Vessels 19(6):275–9. 2004

No intervention

Pattynama PM, Becker GJ, Brown J, Zemel G, Benenati JF, Katzen BT. Percutaneous angioplasty for atherosclerotic renal artery disease: effect on renal function in azotemic patients. Cardiovasc Intervent Radiol 17(3):143–6. 1994

Retrospective (PTRA study)

Paty PS, Darling RC, Lee D, et al. Is prosthetic renal artery reconstruction a durable procedure? An analysis of 489 bypass grafts. J Vasc Surg 34(1):127–32. 2001

N<100 (Surgery study)

Paulsen D, Klow NE, Rogstad B, et al. Preservation of renal function by percutaneous transluminal angioplasty in ischaemic renal disease. Nephrol Dial Transplant 14(6):1454–61. 1999

Retrospective (PTRA study)

Pedersen EB, Jensen FT, Madsen B, Eiskjaer H, Nielsen JT, Rehling M. Angiotensin-converting enzyme inhibitor renography in the diagnosis of renovascular hypertension. Studies before and after angioplasty. Nephrol Dial Transplant 7(12):1178–84. 1992

Retrospective (PTRA study)

Pedersen EB, Madsen B, Danielsen H, Jespersen B. Experience with percutaneous transluminal renal angioplasty in renovascular hypertension. Acta Med Scand Suppl 714:23–7. 1986

N<30 (PTRA study)

Perkovic V, Thomson KR, Becker GJ. Factors affecting outcome after percutaneous renal artery stent insertion. J Nephrol 15(6):649–54. 2002

Retrospective (PTRA study)

Perkovic V, Thomson KR, Mitchell PJ, et al. Treatment of renovascular disease with percutaneous stent insertion: long-term outcomes. Australas Radiol 45(4):438–43. 2001

Retrospective (PTRA study)

Peterson RA, Baldauf CG, Millward SF, Aquino J, Delbrouck N. Outpatient percutaneous transluminal renal artery angioplasty: a Canadian experience. J Vasc Interv Radiol 11(3):327–32. 2000

Retrospective (PTRA study)

Pfeiffer T, Reiher L, Grabitz K, et al. Reconstruction for renal artery aneurysm: operative techniques and long-term results. J Vasc Surg 37(2):293–300. 2003

N<100 (Surgery study)

Pickering TG, Herman L, Devereux RB, et al. Recurrent pulmonary oedema in hypertension due to bilateral renal artery stenosis: treatment by angioplasty or surgical revascularisation. Lancet 2(8610):551–2. 1988

N<30 (PTRA study)

Plouin PF, Darne B, Chatellier G, et al. Restenosis after a first percutaneous transluminal renal angioplasty. Hypertension 21(1):89–96. 1993

Retrospective (PTRA study)

Postma CT, Dennesen PJ, de Boo T, Thien T. First dose hypotension after captopril; can it be predicted? A study of 240 patients. J Human Hypertens 6(3):205–9. 1992

Single dose

Postma CT, Hoefnagels WH, Barentsz JO, de Boo T, Thien T. Occlusion of unilateral stenosed renal arteries--relation to medical treatment. J Human Hypertens 3(3):185–90. 1989

Retrospective (PTRA study)

Poulias GE, Skoutas B, Doundoulakis N, et al. Surgical treatment of renovascular hypertension and respective late results. A twenty years experience. J Cardiovasc Surg 32(1):69–75. 1991

N<100 (Surgery study)

Ramsay LE, Waller PC. Blood pressure response to percutaneous transluminal angioplasty for renovascular hypertension: an overview of published series. BMJ 300(6724):569–72. 1990

Review

Rappelli A, Glorioso N, Madeddu P, et al. Renal vein renin in renovascular hypertension: the experience of two Italian centers. Nephron 44 Suppl 1:12–6. 1986

Retrospective (PTRA)/N<100 (Surgery)

Raynaud AC, Beyssen BM, Turmel-Rodrigues LE, et al. Renal artery stent placement: immediate and midterm technical and clinical results. J Vasc Interv Radiol 5(6):849–58. 1994

Retrospective (PTRA study)

Reams GP, Bauer JH. Enalapril versus triple-drug therapy in the treatment of renovascular hypertension. Drugs 30 Suppl 1:59–69. 1985

N<10 (Medical study)

Reams GP, Singh A, Logan KW, Holmes RA, Bauer JH. Total and split renal function in patients with renovascular hypertension: effects of angiotensin-converting enzyme inhibition. J Clin Hypertens 3(2):153–63. 1987

Retrospective (PTRA study)

Rees CR, Palmaz JC, Becker GJ, et al. Palmaz stent in atherosclerotic stenoses involving the ostia of the renal arteries: preliminary report of a multicenter study. Radiology 181(2):507–14. 1991

N<30 (PTRA study)

Reilly JM, Rubin BG, Thompson RW, Allen BT, Anderson CB, Sicard GA. Long-term effectiveness of extraanatomic renal artery revascularization. Surgery 116(4):784–90. 1994

N<100 (Surgery study)

Reilly JM, Rubin BG, Thompson RW, et al. Revascularization of the solitary kidney: a challenging problem in a high risk population. Surgery 120(4):732–6. 1996

N<100 (Surgery study)

Reisfeld D, Matas AJ, Tellis VA, et al. Late follow-up of percutaneous transluminal angioplasty for treatment of transplant renal artery stenosis. Transplant Proc 21(1 Pt 2):1955–6. 1989

Exclusion population

Ribstein J, Mourad G, Mimran A. Contrasting acute effects of captopril and nifedipine on renal function in renovascular hypertension. Am J Hypertens 1(3 Pt 1):239–44. 1988

Single dose

Rieder CF, Iliopoulos JI, Thomas JH, Pierce GE, Hermreck AS. Trends in reconstruction for atherosclerotic renal vascular disease. Am J Surg 148(6):855–9. 1984

N<100 (Surgery study)

Rodriguez-Lopez JA, Werner A, Ray LI, et al. Renal artery stenosis treated with stent deployment: indications, technique, and outcome for 108 patients. J Vasc Surg 29(4):617–24. 1999

Retrospective (PTRA study)

Rodriguez-Perez JC, Plaza C, Reyes R, et al. Treatment of renovascular hypertension with percutaneous transluminal angioplasty: experience in Spain. J Vasc Interv Radiol 5(1):101–9. 1994

Retrospective (PTRA study)

Rossi G, Feltrin GP, Miotto D, et al. Percutaneous transluminal renal angioplasty: influence of complications on long-term blood pressure results. J Hypertens Suppl 3 Suppl 3:S461–3. 1985

Retrospective (PTRA study)

Rundback JH, Gray RJ, Rozenblit G, et al. Renal artery stent placement for the management of ischemic nephropathy. J Vasc Interv Radiol 9(3):413–20. 1998

Retrospective (PTRA study)

Rundback JH, Jacobs JM. Percutaneous renal artery stent placement for hypertension and azotemia: pilot study. Am J Kidney Dis 28(2):214–9. 1996

N<30 (PTRA study)

Rundback JH, Manoni T, Rozenblit GN, et al. Balloon angioplasty or stent placement in patients with azotemic renovascular disease: a retrospective comparison of clinical outcomes. Heart Dis 1(3):121–5. 1999

Retrospective (PTRA study)

Russo D, Iaccarino V, Conte G, et al. Treatment of severe renovascular hypertension by percutaneous transluminal renal angioplasty in patients with solitary functioning kidney. Effects on blood pressure and renal function. Nephron 50(4):315–9. 1988

N<30 (PTRA study)

Sabeti S, Schillinger M, Mlekusch W, Ahmadi R, Minar E. Reduction in renal function after renal arteriography and after renal artery angioplasty. Eur J Vasc Endovascular Surg 24(2):156–60. 2002

No outcome of interest

Sangle SR, D’Cruz DP, Abbs IC, Khamashta MA, Hughes GR. Renal artery stenosis in hypertensive patients with antiphospholipid (Hughes) syndrome: outcome following anticoagulation. Rheumatology 44(3):372–7. 2005

Exclusion population

Sankari BR, Geisinger M, Zelch M, Brouhard B, Cunningham R, Novick AC. Post-transplant renal artery stenosis: impact of therapy on long-term kidney function and blood pressure control. J Urol 155(6):1860–4. 1996

Exclusion population

Scheinert D, Braunlich S, Nonnast-Daniel B, et al. Transradial approach for renal artery stenting. Catheter Cardiovasc Interv 54(4):442–7. 2001

N<30 (PTRA study)

Schwarten DE. Transluminal angioplasty of renal artery stenosis: 70 experiences. AJR Am J Roentgenol 135(5):969–74. 1980

Pre-1993 (Surgery study)

Schwarten DE. Percutaneous transluminal angioplasty of the renal arteries: intravenous digital subtraction angiography for follow-up. Radiology 150(2):369–73. 1984

Pre-1993 (Surgery study)

Schweiger H, Raithel D, Seyferth W, Zeitler E. Surgical treatment of renal artery occlusive disease: long term results. J Cardiovasc Surg 25(2):111–4. 1984

N<100 (Surgery study)

Senekowitsch C, Assadian A, Wlk MV, Assadian O, Ptakovsky H, Hagmuller GW. Renal artery surgery in the era of endovascular intervention. Vasa 33(4):226–30. 2004

Retrospective (PTRA)/N<100 (Surgery)

Shammas NW, Kapalis MJ, Dippel EJ, et al. Clinical and angiographic predictors of restenosis following renal artery stenting. J Invasive Cardiol. 2004

Retrospective (PTRA study)

Shannon HM, Gillespie IN, Moss JG. Salvage of the solitary kidney by insertion of a renal artery stent. AJR Am J Roentgenol 171(1):217–22. 1998

N<30 (PTRA study)

Sharafuddin MJ, Raboi CA, Abu-Yousef M, Lawton WJ, Gordon JA. Renal artery stenosis: duplex US after angioplasty and stent placement. Radiology 220(1):168–73. 2001

N<30 (PTRA study)

Sharafuddin MJ, Stolpen AH, Dixon BS, Andresen KJ, Sun S, Lawton WJ. Value of MR angiography before percutaneous transluminal renal artery angioplasty and stent placement. J Vasc Interv Radiol 13(9 Pt 1):901–8. 2002

Retrospective (PTRA study)

Shifrin EG, Witz M, Morag B. Revascularisation for a poorly functioning solitary kidney. Eur J Vasc Surg 5(4):421–3. 1991

N<100 (Surgery study)

Sivamurthy N, Surowiec SM, Culakova E, et al. Divergent outcomes after percutaneous therapy for symptomatic renal artery stenosis. J Vasc Surg 39(3):565–74. 2004

Retrospective (PTRA study)

Sos TA, Pickering TG, Sniderman K, et al. Percutaneous transluminal renal angioplasty in renovascular hypertension due to atheroma or fibromuscular dysplasia. N Engl J Med 309(5):274–9. 1983

Retrospective (PTRA study)

Staessen J, Bulpitt C, Fagard R, Lijnen P, Amery A. Long-term converting-enzyme inhibition as a guide to surgical curability of hypertension associated with renovascular disease. Am J Cardiol 51(8):1317–22. 1983

N<100 (Surgery study)

Staessen J, Bulpitt CJ, Fagard R, Lijnen P, Amery A. Long-term converting enzyme inhibition versus surgical treatment in hypertensive patients with renovascular disease. Ne J Med 27(4):161–4. 1984

<6 mo (nd AE)

Staessen J, Wilms G, Baert A, et al. Blood pressure during long-term converting-enzyme inhibition predicts the curability of renovascular hypertension by angioplasty. Am J Hypertens 1(2):208–14. 1988

N<30 (PTRA study)

Steinbach F, Novick AC, Campbell S, Dykstra D. Long-term survival after surgical revascularization for atherosclerotic renal artery disease. J Urol 158(1):38–41. 1997

Pre-1993 (Surgery study)

Sterner G, Weibull H, Hultberg B, et al. Determination of urinary N-acetyl-beta-glucosaminidase in patients with hypertension and renal artery stenosis. J Intern Medicine 234(3):281–5. 1993

Retrospective (PTRA)/N<100 (Surgery)

Strecker EP, Boos I, Schmid G, Gottmann D, Vetter S. Flexible tantalum stents for the treatment of renovascular hypertension: a 10-year experience. Eur Radiol 10(7):1144–51. 2000

Retrospective (PTRA study)

Stribrna J, Belan A, Vesela M, Vojtiskova H, Karasova M. Percutaneous transluminal angioplasty in renovascular hypertension. Cor et Vasa 27(2–3):184–90. 1985

Pre-1993 (Surgery study)

Stribrna J, Hejnal J, Firt P, Belan A, Pirk J, Kramar R. The effect of renal revascularization on decreased glomerular filtration rate in patients with renovascular hypertension. Cor et Vasa 24(1):64–70. 1982

N<100 (Surgery study)

Stuhrmann M, Jahnke T, Roefke C, Cramer BM. Renal artery stenosis: changes in intrarenal Doppler waveform following percutaneous transluminal angioplasty. Cardiovasc Intervent Radiol 21(5):380–5. 1998

<6 mo (nd AE)

Symonides B, Chodakowska J, Januszewicz A, et al. Effects of the correction of renal artery stenosis on blood pressure, renal function and left ventricular morphology. Blood Press 8(3):141–50. 1999

N<30 (PTRA study)

Symonides B, Januszewicz A, Rowinski O, et al. Plasma fibrinogen as a risk factor for restenosis after percutaneous transluminal renal angioplasty in patients with atherosclerotic renal artery stenosis. J Cardiovasc Risk 6(4):269–72. 1999

N<30 (PTRA study)

Szostek M, Malek A, Kulesza A, Naumowski Z, Rowinski O. Early results of percutaneous renal artery angioplasty in patients with renovascular hypertension. Cor et Vasa 29(3):217–21. 1987

N<30 (PTRA study)

Tapper SS, Meacham PW. Multi-branch renal artery lesions: surgical options and results. Cardiovasc Surg 1(6):712–6. 1993

N<100 (Surgery study)

Taylor A, Sheppard D, Macleod MJ, et al. Renal artery stent placement in renal artery stenosis: technical and early clinical results. Clin Radiol 52(6):451–7. 1997

N<30 (PTRA study)

Taylor DC, Houston TM, Anderson C, Jameson M, Popatia S. Follow-up of renal and mesenteric artery revascularization with duplex ultrasonography. Can J Surg 39(1):17–20. 1996

Retrospective (PTRA)/N<100 (Surgery)

Teates CD, Tegtmeyer CJ, Croft BY, Ayers CR. Effects of percutaneous transluminal angioplasty on renal plasma flow. Semin Nucl Med 13(3):245–57. 1983

Retrospective (PTRA study)

Tegtmeyer CJ, Kellum CD, Ayers C. Percutaneous transluminal angioplasty of the renal artery. Results and long-term follow-up. Radiology 153(1):77–84. 1984

Retrospective (PTRA study)

Teunissen KE, Postma CT, van Jaarsveld BC, Derkx FH, Thien T. Endothelin and active renin levels in essential hypertension and hypertension with renal artery stenosis before and after percutaneous transluminal renal angioplasty. J Hypertens 15(12 Pt 2):1791–6. 1997

N<30 (PTRA study)

Torsello G, Sachs M, Kniemeyer H, Grabitz K, Godehardt E, Sandmann W. Results of surgical treatment for atherosclerotic renovascular occlusive disease. Eur J Vasc Surg 4(5):477–82. 1990

Pre-1993 (Surgery study)

Torsello G, Szabo Z, Kutkuhn B, Kniemeyer H, Sandmann W. Ten years experience with reconstruction of the chronic totally occluded renal artery. Eur J Vasc Surg 1(5):327–33. 1987

N<100 (Surgery study)

Tullis MJ, Zierler RE, Glickerman DJ, Bergelin RO, Cantwell-Gab K, Strandness DE. Results of percutaneous transluminal angioplasty for atherosclerotic renal artery stenosis: a follow-up study with duplex ultrasonography. J Vasc Surg 25(1):46–54. 1997

Retrospective (PTRA study)

van Bockel JH, van den Akker PJ, Chang PC, Aarts JC, Hermans J, Terpstra JL. Extracorporeal renal artery reconstruction for renovascular hypertension. J Vasc Surg 13(1):101–10. 1991

N<100 (Surgery study)

van Bockel JH, van Schilfgaarde R, Felthuis W, Heidema J, van Brummelen P, Terpstra JL. Surgical treatment of renovascular hypertension caused by arteriosclerosis. II. Influence of preoperative risk factors and postoperative blood pressure response on late patient survival. Surgery 101(4):468–77. 1987

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, Felthuis W, Hermans J, Terpstra JL. Influence of preoperative risk factors and the surgical procedure on surgical mortality in renovascular hypertension. Am J Surg 155(6):770–5. 1988

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, Felthuis W, Hermans J, van Brummelen P, Terpstra JL. Surgical treatment of renovascular hypertension caused by arteriosclerosis. I. Influence of preoperative factors on blood pressure control early and late after reconstructive surgery. Surgery 101(6):698–705. 1987

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, Felthuis W, Overbosch EH, van Brummelen P, Terpstra JL. Reconstructive surgery for renovascular hypertension. II. Influence of patient selection and anatomical result on the blood pressure response after operation. Qjm 66(251):259–68. 1988

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, Felthuis W, van Brummelen P, Terpstra JL. Reconstructive surgery for renovascular hypertension secondary to arteriosclerosis and fibrodysplasia. III. The early and late effects of surgery on hypertensive target organ damage. Neth J Med 32(3–4):159–71. 1988

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, Overbosch EH, Felthuis W, Terpstra JL. The influence of the surgical technique upon the short term and long term anatomic results in reconstructive operation for renovascular hypertension. Surg Gynecol Obstet 166(5):402–8. 1988

Pre-1993 (Surgery study)

van Bockel JH, van Schilfgaarde R, van Brummelen P, Terpstra JL. Long-term results of renal artery reconstruction with autogenous artery in patients with renovascular hypertension. Eur J Vasc Surg 3(6):515–21. 1989

N<100 (Surgery study)

van Damme H, Jeusette F, Pans A, et al. The impact of renal revascularisation on renal dysfunction. Eur J Vasc Endovascular Surg 10(3):330–7. 1995

N<100 (Surgery study)

van Damme H, Lombet P, Creemers E, Jeusette F, Albert A, Limet R. Surgery for occlusive renal artery disease: immediate and long-term results. Acta Chir Belg 95(1):1–10. 1995

N<100 (Surgery study)

van de Ven PJ, Beutler JJ, Kaatee R, et al. Transluminal vascular stent for ostial atherosclerotic renal artery stenosis. Lancet 346(8976):672–4. 1995

N<30 (PTRA study)

van Jaarsveld BC, Derkx FH, Krijnen P, et al. ’Hypertension resistant to two-drug treatment’ is a useful criterion to select patients for angiography: the ’Dutch Renal Artery Stenosis Intervention Cooperative’ (DRASTIC) study. Contrib Nephrol 119:54–8. 1996

No intervention

Vogt PA, Pairolero PC, Hollier LH, Fowl RJ, Cherry KJ, Bernatz PE. The occluded renal artery: durability of revascularization. J Vasc Surg 2(1):125–32. 1985

N<100 (Surgery study)

von Knorring J, Edgren J, Lepantalo M. Long-term results of percutaneous transluminal angioplasty in renovascular hypertension. Acta Radiol 37(1):36–40. 1996

Retrospective (PTRA study)

von Knorring J, Lepantalo M, Fyhrquist F. Long-term prognosis of surgical treatment of renovascular hypertension. J Intern Medicine 225(5):303–9. 1989

N<100 (Surgery study)

Watson PS, Hadjipetrou P, Cox SV, Piemonte TC, Eisenhauer AC. Effect of renal artery stenting on renal function and size in patients with atherosclerotic renovascular disease. Circulation 102(14):1671–7. 2000

N<30 (PTRA study)

Weaver FA, Kuehne JP, Papanicolaou G. A recent institutional experience with renovascular hypertension. Am Surg 62(3):241–5. 1996

Retrospective (PTRA)/N<100 (Surgery)

Weibull H, Bergqvist D, Bergentz SE, Jonsson K, Hulthen L, Manhem P. Percutaneous transluminal renal angioplasty versus surgical reconstruction of atherosclerotic renal artery stenosis: a prospective randomized study. J Vasc Surg 18(5):841–50. 1993

RCT of PTRA v surgery, not v medical. N<30 (PTRA)/Pre-1993 (Surgery)

Weibull H, Bergqvist D, Jendteg S, et al. Clinical outcome and health care costs in renal revascularization--percutaneous transluminal renal angioplasty versus reconstructive surgery. Br J Surg 78(5):620–4. 1991

Retrospective (PTRA)/N<100 (Surgery)

Weibull H, Bergqvist D, Jonsson K, Carlsson S, Takolander R. Analysis of complications after percutaneous transluminal angioplasty of renal artery stenoses. Eur J Vasc Surg 1(2):77–84. 1987

Retrospective (PTRA study)

Weibull H, Bergqvist D, Jonsson K, Hulthen L, Mannhem P, Bergentz SE. Long-term results after percutaneous transluminal angioplasty of atherosclerotic renal artery stenosis--the importance of intensive follow-up. Eur J Vasc Surg 5(3):291–301. 1991

Pre-1993 (Surgery study)

Wenting GJ, Tan-Tjiong HL, Derkx FH, de Bruyn JH, Man i, Schalekamp MA. Splint renal function after captopril in unilateral renal artery stenosis. BMJ 288(6421):886–90. 1984

<6 mo (nd AE)

Whelton PK, Harris AP, Russell RP, et al. Renovascular hypertension: results of medical and surgical therapy. Johns Hopkins Med J 149(6):213–9. 1981

Pre-1993 (Surgery study)

Wilms G, Staessen J, Baert AL, Michielsen P, Amery A. Percutaneous transluminal renal angioplasty and renal function. Radiologe 29(4):195–200. 1989

Pre-1993 (Surgery study)

Wilms GE, Baert AL, Amery AK, Staessen JA, Vermylen JG. Short-term morphologic results of percutaneous transluminal renal angioplasty as determined with angiography. Radiology 170(3 Pt 2):1019–21. 1989

Pre-1993 (Surgery study)

Wilms GE, Peene PT, Baert AL, et al. Renal artery stent placement with use of the Wallstent endoprosthesis. Radiology 179(2):457–62. 1991

N<30 (PTRA study)

Wong JM, Hansen KJ, Oskin TC, et al. Surgery after failed percutaneous renal artery angioplasty. J Vasc Surg 30(3):468–82. 1999

N<100 (Surgery study)

Xue F, Bettmann MA, Langdon DR, Wivell WA. Outcome and cost comparison of percutaneous transluminal renal angioplasty, renal arterial stent placement, and renal arterial bypass grafting. Radiology 212(2):378–84. 1999

Retrospective (PTRA)/N<100 (Surgery)

Young N, Gruenewald SM, Wong KP. Technetium-99m DTPA renography and angiography in renal artery stenosis of varying severity. Australas Radiol 38(1):24–9. 1994

Retrospective (PTRA study)

Young N, Wong KP. Use of percutaneous transluminal balloon angioplasty to treat renovascular disease. Australas Radiol 36(4):289–93. 1992

Retrospective (PTRA study)

Yutan E, Glickerman DJ, Caps MT, et al. Percutaneous transluminal revascularization for renal artery stenosis: Veterans Affairs Puget Sound Health Care System experience. J Vasc Surg 34(4):685–93. 2001

Retrospective (PTRA study)

Zech P, Finaz d, Pozet N, et al. Surgical versus medical treatment in renovascular hypertension. Retrospective study of 166 cases. Nephron 44 Suppl 1:105–8. 1986

Retrospective (Medical)/N<100 (Surgery)

Zeller T, Muller C, Frank U, et al. Stent angioplasty of severe atherosclerotic ostial renal artery stenosis in patients with diabetes mellitus and nephrosclerosis. Catheter Cardiovasc Interv 58(4):510–5. 2003

Retrospective (PTRA study)

Zhang Q, Shen W, Zhang R, Zhang J, Hu J, Zhang X. Effects of renal artery stenting on renal function and blood pressure in patients with atherosclerotic renovascular disease. Chin Med J 116(10):1451–4. 2003

Retrospective (PTRA study)

Ziegelbaum M, Novick AC, Hayes J, Vidt DG, Risius B, Gifford RW. Management of renal arterial disease in the elderly patient. Surg Gynecol Obstet 165(2):130–4. 1987

Retrospective (PTRA)/N<100 (Surgery)

Zierler RE, Bergelin RO, Davidson RC, Cantwell-Gab K, Polissar NL, Strandness DE. A prospective study of disease progression in patients with atherosclerotic renal artery stenosis. Am J Hypertens 9(11):1055–61. 1996

No outcome of interest

Zimbler MS, Pickering TG, Sos TA, Laragh JH. Proteinuria in renovascular hypertension and the effects of renal angioplasty. Am J Cardiol 59(5):406–8. 1987

Pre-1993 (Surgery study)

Zuccala A, Losinno F, Gaggi R, Zucchelli P. Late improvement of renal function in patients treated by percutaneous transluminal renal angioplasty. Contrib Nephrol 119:74–7. 1996

Retrospective (PTRA study)