# Search Strategy

## MEDLINE 1966-August Week 4 2005

# | Search History | Results
1 | exp Hypertension, Renal/ | 15140
2 | exp Renal Artery Obstruction/ | 7388
3 | renal arter$ stenosis.tw. | 3264
4 | renal arter$ dis$.tw. | 390
5 | renovascular dis$.tw. | 613
6 | reno vascular dis$.tw. | 6
7 | renal vascular dis$.tw. | 156
8 | (arvd or “atherosclerotic renovascular dis$”).tw. | 302
9 | renal steno$.tw. | 49
10 | steno$ kidney.tw. | 137
11 | renovascular steno$.tw. | 27
12 | or/1–11 | 20249
13 | limit 12 to humans | 15628
14 | limit 13 to english language limit 14 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or | 10148
15 | dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index or “review of reported cases”) | 2736
16 | 14 not 15 | 7412
17 | limit 16 to “all adult (19 plus years)” | 4222
18 | 16 not 17 | 3190
19 | limit 18 to “all child (0 to 18 years)” | 488
20 | 16 not 19 | 6924
21 | limit 20 to (guideline or practice guideline or “review” or review, academic or “review literature” or review, multicase or review, tutorial) | 1316
22 | limit 20 to meta analysis | 8
23 | 20 not (21 or 22) | 5601
24 | follow-up studies/ | 303611
25 | (follow-up or followup).tw. | 332435
26 | exp Case-Control Studies/ | 288665
27 | (case adj20 control).tw. | 43581
28 | exp Longitudinal Studies/ | 498762
29 | longitudinal.tw. | 61304
30 | exp Cohort Studies/ | 536922
31 | cohort.tw. | 70605
32 | (random$ or rct).tw. | 315873
33 | exp Randomized Controlled Trials/ | 38577
34 | exp random allocation/ | 53586
35 | exp Double-Blind Method/ | 82631
36 | exp Single-Blind Method/ | 9171
37 | randomized controlled trial.pt. | 204593
38 | clinical trial.pt. | 412355
39 | controlled clinical trials/ | 2929
40 | (clin$ adj trial$).tw. | 88180
41 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 79196
42 | exp PLACEBOS/ | 23902
43 | placebo$.tw. | 90025
44 | exp Research Design/ | 194218
45 | exp Evaluation Studies/ | 529271
46 | exp Prospective Studies/ | 190597
47 | exp Comparative Study/ | 1211784
48 | or/24–47 | 2748065
49 | 23 and 48 | 2167