# Appendixes

Appendix A Search Strategy

Appendix B Sample Data Extraction Form

Appendix C Excluded Studies

Appendix D Peer Reviewers

Appendix E Detailed Mortality Figure

Appendix F Detailed Summary Table