# Technical Expert Panel

David Ahlquist, M.D.

Gastroenterology, Mayo Clinic

Rochester, MN

James Allison, M.D., F.A.C.P.

Gastroenterology, UC San Francisco

Division of Research, Kaiser Permanente

Oakland, CA

Mary Barton, M.D., M.P.P.

(At the time of the review)

Scientific Director

U.S. Preventive Services Task Force

Agency for Healthcare Research and Quality

Rockville, MD

Barry Berger, M.D.

Chief Medical Officer, Exact Sciences

Madison, WI

Doug Campos-Outcalt, M.D., M.P.A.

Associate Head, Clinical Professor

University of Arizona

Phoenix, AZ

Theodore Ganiats, M.D.

Professor/Chair, Family & Prev Medicine

Cancer Prevention & Control Program

University of California San Diego

San Diego, CA

Michael Lawson, M.D.

Department of Gastroenterology

Permanente Medical Group, Kaiser Permanente

Sacramento, CA

Margaret Piper, Ph.D., M.P.H.

Director, Genomics Resources

BlueCross BlueShield Association

Technology Evaluation Center

Chicago, IL