# Summary and Discussion

## Strength and Applicability of Evidence

Despite considerable media attention and expert-based clinical recommendations that include fecal DNA testing as an option for CRC screening, there is currently insufficient evidence regarding the clinical accuracy (or clinical validity) for fecal DNA tests in patients at average- risk for CRC (Table 11). Few studies use appropriate study designs to determine screening test accuracy in asymptomatic populations, and these studies do not evaluate clinically available fecal DNA tests.

Table 11 Strength of evidence for fecal DNA testing

Outcome (key question) | # studies (n pts) | Study design | Risk of bias | Consistency | Directness | Precision | Strength of evidence
Morbidity or mortality (KQ1) | None | - | - | - | - | - | Insufficient
Test performance (KQ2) | 3 (n=5662) | Diagnostic accuracy studies | Medium | Inconsistent (2 studies) | Indirect | Imprecise | Insufficient
Test performance, interval (KQ3) | None | - | - | - | - | - | Insufficient
Analytic validity (KQ4) | 3 (not applicable) | In vitro laboratory studies | High | Not applicable (no replication) | Indirect | Imprecise | Insufficient
Acceptability Adherence (KQ5) | 6 (n=8013) 2 (n=9968) | Cohort, cross-sectional | High | Consistent | Indirect | Imprecise | Insufficient
Harms-diagnostic inaccuracy (KQ6) | 3 (n=5662) | Diagnostic accuracy studies | Medium | Consistent | Indirect | Imprecise | Insufficient

We found only three studies that evaluated the performance of fecal DNA tests in asymptomatic persons. The best evidence is from two studies (n analyzed=5004) that evaluated a multi-marker fecal DNA test that was a prototype to a later version that was clinically available as PreGen Plus™.33,34 The sensitivity to detect CRC for this prototype was discordant between two studies (25 percent [95% CI, 5 to 57] versus 51.6 percent, [95% CI, 34.8 to 68.0]), although the confidence intervals overlapped. Sensitivity for advanced adenomas was similarly poor in both studies (19 percent [95% CI, 5 to 42] and 15.1 percent, [95% CI, 12.0 to 19.0]). Between-study differences, such as differences in study populations, do not clearly account for differences in test sensitivities. Specificity for any screen-relevant neoplasm (CRC and advanced adenoma) ranged from 93.6 percent (95% CI, 92.9 to 94.3) to 96 percent (95% CI, 95 to 97). Hemoccult II™ performed unusually poorly in both of these studies, with sensitivity for CRC of 12.9 percent (95% CI, 5.1 to 28.9) and 11 percent (95% CI, 6 to 16). Best, and generally accepted, estimates for sensitivity of Hemoccult II for CRC ranges from 25 to 38 percent, with 98 to 99 percent specificity for CRC.103 Accurate interpretation of Hemoccult II requires training and supervision, especially when interpreting borderline results, and therefore the lower sensitivities of Hemoccult II in these two studies and real-world settings may be indicative of suboptimal (poor) oversight and standardization of the lab development of Hemoccult II.111-113 Other available stool-based tests have been shown to have much higher sensitivities (but with lower specificity) for CRC. Best estimates for Hemoccult SENSA™ for CRC are approximately 64 to 80 percent sensitivity and 87 to 90 percent specificity.5 Although FITs represent a very heterogeneous group of tests, sensitivity for CRC appears to range from about 61 to 91 percent, and specificity ranges from 91 to 98 percent.5 Hemoccult SENSA and the various FITs have not been as well studied as Hemocccult II, but it is clear that they also have similar issues around quality assurance (e.g., accurate interpretation, number of samples) and therefore real-world performance estimates may be lower than those previously reported.5,10 Furthermore, these estimates of sensitivity and specificity are based on a single test application. The overall test performance of these stool-based tests in a program of screening will depend on the interval between repeated screening (and adherence to testing), which varies between the different types of stool-based testing. Thus far, only Hemoccult II has randomized controlled trial evidence to show that a program of (bi-) annual screening can reduce mortality.5,114

Due to the differences in tests evaluated and differences in sensitivity between the two studies that evaluated the same test, the evidence for the test accuracy for fecal DNA testing is both inconsistent and imprecise. Fecal DNA test development has evolved significantly over the past decade (and continues to develop), reflecting advances in the understanding of molecular markers that reflect neoplastic change and ongoing advances in technologies to stabilize, extract, and amplify/detect low levels of human target DNA in stool samples. Therefore the only three studies on test performance of fecal DNA tests in screening populations do not reflect the current commercially available fecal DNA test (or soon to be available fecal DNA testing).

Likewise, harms and acceptability of, and adherence to, fecal DNA testing also have insufficient evidence (Table 11) and are largely not applicable to currently available fecal DNA tests. Because test preference is influenced by test performance, acceptability, and adherence to testing will need to be reexamined once test performance is known. In addition, acceptability and adherence should be examined in comparison to other stool-based screening methods, specifically FITs, which do not require any dietary or medication restrictions. Subtleties in stool collection (e.g., number of samples; cards versus vials versus whole stool) may also affect acceptability and adherence, and therefore may change if future fecal DNA testing no longer requires a single whole stool specimen. Currently, there is no evidence that directly addresses health benefit (or clinical utility) or intervals of screening for fecal DNA testing. Experts suggest that new diagnostic tests may be substituted for an established test based on diagnostic accuracy studies alone if the new test is clinically superior to existing tests (e.g., safer or more specific than, but of similar sensitivity to, the established test).115 After test performance in screening populations is established, and if the test is not obviously clinically superior to existing tests, modeling using robust CRC screening models (MISCAN, SimCRC) could inform net health benefit (e.g., tradeoffs from improved sensitivity and reduced specificity) and optimal intervals of screening using fecal DNA testing.

## Evidence Gaps

In order to understand the clinical utility of fecal DNA testing, clinicians and decision-makers need evidence to inform the net benefit and comparative effectiveness of fecal DNA testing in screening asymptomatic persons for CRC. Table 12 outlines the development of research for fecal DNA screening tests. While different decision-makers may have different thresholds for the types of evidence required to consider a test for clinical use (e.g., may not require evidence of clinical utility), most would agree that robust evidence on the clinical test validation in the intended population would be the minimum evidence required for clinical decision making. Presently, there is no such evidence on test performance (diagnostic accuracy and inaccuracy) in a screening population for either currently available testing or soon-to-be-available testing. Evidence about optimal screening intervals, analytic validity, and acceptability of adherence (helpful in understanding the implementation of screening and the real world effectiveness of screening) are also generally lacking. Evidence thus far has primarily focused on initial test validation of an evolving series of tests (Table 12). However, clinical decision making cannot rely on initial test validation results alone, especially when viable alternative tests exist (other CRC screening tests including stool based testing).115 Empiric evidence shows that distorted selection of participants (including non-representative patients) and use of case-control study designs overestimate overall test accuracy due to both variation and spectrum bias.39,40

Table 12 Evidence landscape for fecal DNA testing

Phases of test development | Description | Available evidence
Marker identification and assay development | To identify molecular alterations associated with colorectal cancer To develop assays that can detect these alterations in tumors and in stool samples | Likely numerous studies, often unpublished, our review only included studies on analytic validity of currently available testing (n=1) and not other aspects of assay development
Initial test validation and assay refinement | To determine ability and accuracy of test in persons with CRC or advanced adenomas To develop technological improvements to assays | Numerous studies (N>60) on different assays/markers Limited evidence for analytic validity of currently available testing (n=2), often unpublished
Test validation in intended population and generalizability | To determine diagnostic accuracy for detection of CRC or advanced adenomas of test in screening population To determine factors affecting application and test performance in real-world setting (including test feasibility and acceptability) | Limited studies (n=3) evaluating test performance of different tests, none of which are applicable to currently available testing Limited studies (n=5) evaluating acceptability of fecal DNA tests (no studies compared fecal DNA to FIT acceptability)
Clinical test performance and health impact | To compare the effectiveness and harms of fecal DNA testing versus established screening alternatives on health outcomes | No direct evidence (modeling exercises can be valuable, if good estimates of diagnostic accuracy are available)
Net benefit of testing, cost-effectiveness | To determine population net benefit or cost-effectiveness of fecal DNA screening in a program of repeated screening (compared to relevant screening options) | No direct evidence, cost-effectiveness not addressed in this review (modeling exercises can be valuable, if good estimates of diagnostic accuracy are available)

Our review is consistent with these findings. When we compare the results from the three included studies with the initial validation studies identified, but excluded from this review, we found exaggerated sensitivities in these studies excluded for their high potential bias. For example, initial validation studies for the prototype of PreGen Plus had sensitivity for CRC estimates around 90 percent, and subsequent test validation studies in screening populations showed much lower sensitivities (about 25 to 50 percent).15 In addition, independent validation of tests in a larger and (more) representative cohort can reveal “implementation” issues that can also affect test performance in a clinical setting. For example, authors suggest that the diagnostic accuracy study by Imperiale and colleagues had a much lower sensitivity than anticipated because of DNA degradation during the transport and storage of the stool sample, which led to the subsequent development and addition of a buffer to stabilize the target DNA in stool samples.17 Although CRC is not uncommon, prospectively designed diagnostic accuracy studies for colorectal cancer screening need to be quite large to accrue enough cancer outcomes, especially in average-risk adults. Well conducted nested case-control designs similar to the included Ahlquist and Imperiale studies can provide valuable diagnostic accuracy information. The cases and controls should be nested in a screening population and the index test (fecal DNA test) should be conducted on stool samples acquired before the colonoscopy, as the colonoscopy is often therapeutic in removing suspicious lesions.

Therefore, the most critical evidence gap for fecal DNA testing to screen for CRC is the lack of appropriately designed diagnostic accuracy studies applicable to currently available fecal DNA testing. While we found no evidence to specifically address harms of testing, we do not expect any clinically significant harms other than the (unnecessary) downstream effects of testing and complications from testing resulting from false positives, or clinically significant sequelae from missed diagnosis resulting from false negatives. Potential harms due to diagnostic inaccuracy should therefore be weighed in comparison to the diagnostic inaccuracy from other non-invasive stool based testing. While some degree of worry could be engendered by being offered fecal DNA testing, evidence to support clinically meaningful negative psychological impacts from stool based screening or the negative impacts of fecal DNA testing compared to other stool based tests does not exist.116 Ultimately, the issue of considering the net benefit of fecal DNA testing compared to the best CRC screening alternative(s) may require some degree of modeling, especially without clearly superior new testing115 or applicable comparative effectiveness trials reporting health outcomes (which may never happen given the rapid evolution of fecal DNA testing).

When better quality, more applicable diagnostic accuracy studies in screening populations become available, clinicians and decision makers can use robust models that have been developed by the National Cancer Institute (NCI) Cancer Intervention and Surveillance Modeling Network (CISNET) for evaluating CRC screening to estimate net benefit of testing and optimal intervals of testing, compared to other currently used or promising screening modalities. In 2007, the Centers for Medicare and Medicaid Services (CMS) commissioned to CISNET to do a cost-effectiveness analysis of screening with fecal DNA testing in support of a National Coverage Determination process to determine whether PreGen Plus, version 1.1 should be covered for Medicare enrollees.117 Based on two independently conducted microsimulation models (MISCAN and SimCRC), the cost-effectiveness of fecal DNA testing was modeled for fecal DNA test every 3 or 5 years to screen for a cohort of patients at average-risk for CRC aged 65 years compared to other screening modalities (Hemoccult II, Hemoccult SENSA, FIT, flexible sigmoidoscopy, and colonoscopy) enrollees.117 Based on these modeling exercises, the investigators found that at $350 per test, fecal DNA testing would not be cost-effective regardless of sensitivity and specificity at any level of test accuracy. They found that that fecal DNA testing would be cost-effective at a per-test cost of $40 to $60 (depending on the model used), if used every 3 years. Fecal DNA testing, however, could be effective at current cost if the relative adherence to fecal DNA testing was at least 50 percent better than that with other screening tests.

Although modeling exercises can use sensitivity analyses around test adherence to see if the comparative effectiveness between different screening tests is robust to variation and differential test adherence, understanding issues around patient acceptability and actual adherence to fecal DNA testing is still quite important. The most important driver of poor early detection of CRC is not the less-than-perfect sensitivities of different screening tests, but the suboptimal uptake of screening tests. Advocates in the field have stated that the best screening test is the test that is completed. Therefore, if fecal DNA testing can improve uptake of CRC screening because it appeals to persons who are unscreened or under screened, it could have a significant clinical and public health benefit. Existing studies, albeit limited, seem to consistently identify factors that influence patient preferences around testing. Patients prefer tests that are non-invasive, require no pain or preparation, are highly accurate, do not require (frequently) repeated testing, and cause no complications. Stool-based tests that require little to no preparation, like fecal DNA testing or FITs, may be preferable to patients, although both would require repeated testing. Currently there is no evidence about the relative preference and adherence between fecal DNA testing and FITs. In addition to understanding the comparative test performance between these two types of testing, any differences in preference and adherence between these tests will also be important. Subtleties in stool collection may also affect acceptability and adherence, and therefore preference and adherence studies must be specific to particular tests because the test accuracy and method/details of stool collection may even vary between different fecal DNA and FIT tests.

Finally, issues around the fecal DNA test's analytic validity are important to address since these issues/factors can help inform understanding of clinical validity of a test as well as inform what may be needed for post implementation monitoring and quality control. Analytic validity is the assay's ability to accurately and reliably measure the genotype.105 Diagnostic tests subject to FDA approval must provide evidence on the accuracy in, and reliability of, measuring the analyte (or genotype) of interest.118 Our review of analytic validity focused on the accuracy, lower limit of detection, analytic specificity, repeatability and reproducibility of fecal DNA assays for methylated vimentin (the basis of ColoSureTM). We located only three relevant studies despite searching non-published and grey literature. We found no evidence on the overall analytic validity of methylated vimentin fecal DNA testing. We found one early proof-of-concept paper focusing on experiments showing that testing for methylated vimentin as a marker for CRC was possible (in tumor tissue), and two studies with experiments evaluating specific technologies (methyl-BEAMing, and methyl-binding domain enrichment) and their ability to improve the lower limit of detection for target DNA in stool. We found no evidence on the repeatability or reproducibility of the currently available fecal DNA test on methylated vimentin. These two dimensions of analytic validity are clinically relevant to larger-scale implementation of testing and quality assurance of testing once implemented, especially as fecal DNA testing becomes more complicated. This may result from including multiple molecular markers and more advanced or combinations of technologic components because there may be more opportunities for variations in important pre-analytic and analytic factors. Reporting of potentially important details that may affect analytic validity of assays should be routinely reported in clinical evaluation studies, so it is transparent from the studies differences in the conduct of the test between studies and between research and clinical practice (implementation). Especially given the constant changes in test development, test developers and researchers need to be transparent and explicit about differences in the assays evaluated in studies and the actual assays that are clinically available.

## Limitations

Based on this systematic review, we know that fecal DNA test research and development is a continuously evolving field. The limitations in this review primarily stem from the limitations in the primary research and the moving target nature of fecal DNA testing (resulting in a mismatch between primary research and available testing). However, there are a few important limitations in scope and timing of this review. Our review focused on fecal DNA testing to screen for CRC, and therefore did not address other potential roles of fecal DNA testing (i.e., in a diagnostic algorithm for individuals at high risk for developing CRC, monitoring or surveillance of individuals with previously abnormal screening results, or as a prognostic test or test for treatment prediction once cancer is diagnosed). Our review also did not address the specific role of fecal DNA screening to detect clinically significant lesions traditionally missed by colonoscopy, i.e., flat lesions; or the clinical significance of a positive fecal DNA test result in light of a negative colonoscopy. In addition, our review did not include stool-based RNA testing or other genetic/genomic based testing in plasma. However, these newer types of genetic/genomic testing to screen for CRC are more developmental than fecal DNA testing. Given the rapidly evolving nature of fecal DNA testing, this review will likely be out of date in the near future, as new tests and evidence supporting them become available in the next 1 to 2 years. However, many of the issues laid out in the report will be helpful framing the evaluation of the evidence based in the future.