# References

1 American Cancer Society. Colorectal Cancer Facts & Figures 2011-2013. Atlanta. American Cancer Society. 2011.
2 SEER Cancer Statistics Review, 1975-2008. National Cancer Institute. 2011.
3 Richardson LC, Tai E, Rim SH, et al. Vital signs: colorectal cancer screening, incidence, and mortality — United States, 2002--2010. Morbidity and Mortality Weekly Report. Jul. 8. 2011;60(26):884-89. [pmid: 21734636].
4 American Cancer Society. Cancer Facts & Figures 2010. No. 500810. Atlanta. 2010.
5 Whitlock EP, Lin J, Liles E, et al. Screening for colorectal cancer: an updated systematic review. Report No. 08-05-05124-EF-1. Rockville, MD. Agency for Healthcare Research & Quality. 2008. [pmid: 20722162].
6 Soetikno RM, Kaltenbach T, Rouse RV, et al. Prevalence of nonpolypoid (flat and depressed) colorectal neoplasms in asymptomatic and symptomatic adults. JAMA. Mar. 5. 2008;299(9):1027-35. [pmid: 18319413].
7 Young GP, Bosch LJ. Fecal tests: from blood to molecular markers. Curr Colorectal Cancer Rep. Mar. 2011;7(1):62-70. [pmid: 21423316].
8 Markowitz SD, Bertagnolli MM. Molecular basis of colorectal cancer. New England Journal of Medicine. Dec. 17. 2009;361(25):2449-60. [pmid: 20018966].
9 Holden DJ, Jonas DE, Porterfield DS, et al. Systematic review: Enhancing the use and quality of colorectal cancer screening. Ann Intern Med. 2010;2010(10):668-76. [pmid: 20388703].
10 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Gastroenterology. Mar. 5. 2008;58(5):130-60. [pmid: 18322143].
11 Agency for Healthcare Research and Quality. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149(9):627-37. [pmid: 18838716].
12 Burt RW. Colorectal cancer screening. Curr Opin Gastroenterol. Sep. 2010;26(5):466-70. [pmid: 20664346].
13 Rex DK, Johnson DA, Anderson JC, et al. American College of Gastroenterology guidelines for colorectal cancer screening 2009 [corrected]. Am J Gastroenterol. 2009;2009(3):739-50. [pmid: 19240699].
14 Anderson WF, Guyton KZ, Hiatt RA, et al. Colorectal cancer screening for persons at average risk. J Natl Cancer Inst. Aug. 7. 2002;94(15):1126-33. [pmid: 12165637].
15 Bosch LJ, Carvalho B, Fijneman RJ, et al. Molecular tests for colorectal cancer screening. Clin Colorectal Cancer. Mar. 1. 2011;10(1):8-23. [pmid: 21609931].
16 Potack J, Itzkowitz SH. Practical advances in stool screening for colorectal cancer. J Natl Compr Canc Netw. Jan. 2010;8(1):81-92. [pmid: 20064291].
17 Ahlquist DA. Molecular detection of colorectal neoplasia. Gastroenterology. Jun. 2010;138(6):2127-39. [pmid: 20420950].
18 Kisiel JB, Ahlquist DA. Stool DNA screening for colorectal cancer: opportunities to improve value with next generation tests. J Clin Gastroenterol. Apr. 2011;45(4):301-08. [pmid: 20856138].
19 van Dam L, Kuipers EJ, van Leerdam ME. Performance improvements of stool-based screening tests. Best Pract Res Clin Gastroenterol. Aug. 2010;24(4):479-92. [pmid: 20833351].
20 Ahlquist DA, Skoletsky JE, Boynton KA, et al. Colorectal cancer screening by detection of altered human DNA in stool: feasibility of a multitarget assay panel. Gastroenterology. Nov. 2000;119(5):1219-27. [pmid: 11054379].
21 Tagore KS, Lawson MJ, Yucaitis JA, et al. Sensitivity and specificity of a stool DNA multitarget assay panel for the detection of advanced colorectal neoplasia. Clin Colorectal Cancer. May. 2003;3(1):47-53. [pmid: 12777192].
22 Calistri D, Rengucci C, Bocchini R, et al. Fecal multiple molecular tests to detect colorectal cancer in stool. Clin Gastroenterol Hepatol. Sep. 2003;1(5):377-83. [pmid: 15017656].
23 Brand RE, Ross ME, Shuber AP. Reproducibility of a multitarget stool-based DNA assay for colorectal cancer detection. Am J Gastroenterol. Jul. 2004;99(7):1338-41. [pmid: 15233675].
24 Syngal S, Stoffel E, Chung D, et al. Detection of stool DNA mutations before and after treatment of colorectal neoplasia. Cancer. Jan. 15. 2006;106(2):277-83. [pmid: 16342248].
25 Whitney D, Skoletsky J, Moore K, et al. Enhanced retrieval of DNA from human fecal samples results in improved performance of colorectal cancer screening test. J Mol Diagn. Nov. 2004;6(4):386-95. [pmid: 15507679].
26 Olson J, Whitney DH, Durkee K, et al. DNA stabilization is critical for maximizing performance of fecal DNA-based colorectal cancer tests. Diagn Mol Pathol. Sep. 2005;14(3):183-91. [pmid: 16106201].
27 Itzkowitz SH, Jandorf L, Brand R, et al. Improved fecal DNA test for colorectal cancer screening. Clini Gastroenterol Hepatol. Jan. 2007;5(1):111-17. [pmid: 17161655].
28 Itzkowitz S, Brand R, Jandorf L, et al. A simplified, noninvasive stool DNA test for colorectal cancer detection. Am J Gastroenterol. Nov. 2008;103(11):2862-70. [pmid: 18759824].
29 Chen WD, Han ZJ, Skoletsky J, et al. Detection in fecal DNA of colon cancer-specific methylation of the nonexpressed vimentin gene. J Natl Cancer Inst. Aug. 3. 2005;97(15):1124-32. [pmid: 16077070].
30 Baek YH, Chang E, Kim YJ, et al. Stool methylation-specific polymerase chain reaction assay for the detection of colorectal neoplasia in Korean patients. Dis Colon Rectum. Aug. 2009;52(8):1452-59. [pmid: 19617759].
31 Li M, Chen WD, Papadopoulos N, et al. Sensitive digital quantification of DNA methylation in clinical samples. Nature Biotechnology. Sep. 2009;27(9):858-63. [pmid: 19684580].
32 Zou H, Allawi H, Cao X, et al. Sensitive quantification of vimentin methylation with a novel methylation specific qInvader technology. Clinical Chemistry. Sep. 2010;56(6 Suppl.):D-144.
33 Imperiale TF, Ransohoff DF, Itzkowitz SH, et al. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. 2004;2004(26):2704-14. [pmid: 15616205].
34 Ahlquist DA, Sargent DJ, Loprinzi CL, et al. Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. Oct. 1. 2008;149(7):441-50. [pmid: 18838724].
35 DNA Direct. Who Should Consider ColoSure™ Colon Cancer Screening?. San Francisco. DNA Direct Incorporated. 2011. https://www.dnadirect.com/web/article/screening-tests/colosure-stool-dna-testing/24/who-should-consider-screening. July 20, 2011.
36 Shuren J. Direct-to-Consumer Genetic Testing and the Consequences to the Public (congressional testimony). Silver Spring, MD. U.S. Food and Drug Administration. 2010. http://www.fda.gov/NewsEvents/Testimony/ucm219925.htm. December 6, 2010.
37 Exact Sciences Fourth-Quarter & Full-Year 2010 Earnings Call>2011 Feb 15 Madison, WI Exact Sciences Corporation 2011
38 Whitlock EP, Lopez S, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
39 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061-66. [pmid: 10493205].
40 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. Feb. 3. 2004;140(3):189-202. [pmid: 14757617].
41 Agency for Healthcare Research and Quality. U.S. Preventive Services Task Force Procedure Manual. http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. AHRQ Publication No.08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
42 Teutsch SM, Bradley LA, Palomaki GE, et al. The evaluation of genomic applications in practice and prevention (EGAPP) initiative: methods of the EGAPP working group. Genet Med. Jan. 2009;11(1):3-14. [pmid: 18813139].
43 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa. Ottawa Hospital Research Institute. 2011. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. March 11, 2011.
44 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
45 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
46 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011. [pmid: 21463926].
47 Haug U, Hillebrand T, Bendzko P, et al. Mutant-enriched PCR and allele-specific hybridization reaction to detect K-ras mutations in stool DNA: high prevalence in a large sample of older adults. Clinical Chemistry. Apr. 2007;53(4):787-90. [pmid: 17317884].
48 Tang D, Liu J, Wang DR, et al. Diagnostic and prognostic value of the methylation status of secreted frizzled-related protein 2 in colorectal cancer. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 2011;34(2):E88. [pmid: 21463549].
49 Zhang H, Wang X, Ma Q, et al. Rapid detection of low-abundance K-ras mutation in stools of colorectal cancer patients using chip-based temperature gradient capillary electrophoresis. Lab Invest. 2011. Jan. 17. [pmid: 21242956].
50 Zhang J, Yang S, Xie Y, et al. Detection of methylated tissue factor pathway inhibitor 2 and human long DNA in fecal samples of patients with colorectal cancer in China. Cancer Epidemiol. 2011. May. 26. [pmid: 21621497].
51 Ahlquist D, Domanico M, Mahoney DW, et al. Next Generation Stool DNA Testing for Detection of Colorectal Neoplasia: Early Marker Evaluation–Poster Presentation. Exact Sciences Corporation. 2011.
52 Azuara D, Rodriguez-Moranta F, de Oca J, et al. Novel methylation panel for the early detection of colorectal tumors in stool DNA. Clin Colorectal Cancer. Jul. 2010;9(3):168-76. [pmid: 20643622].
53 Chang E, Park DI, Kim YJ, et al. Detection of colorectal neoplasm using promoter methylation of ITGA4, SFRP2, and p16 in stool samples: a preliminary report in Korean patients. Hepato-Gastroenterology. Jul. 2010;57(101):720-27. [pmid: 21033217].
54 Hussain FT, Harrington JJ, Yab TC. Detection of serrated colorectal polyps by stool DNA testing. General Poster Session C: Cancers of the Colon and Rectum. 2010 Gastrointesinal Symposium. Orlando, FL. 2010.
55 Kalimutho M, Blanco GV, Gravina P, et al. Quantitative denaturing high performance liquid chromatography (Q-dHPLC) detection of APC long DNA in faeces from patients with colorectal cancer. Clin Chem Lab Med. Sep. 2010;48(9):1303-11. [pmid: 20504269].
56 Kisiel JB, Yab TC, Hussain FT, et al. Noninvasive detection of colorectal neoplasia (CRN) in inflammatory bowel disease (IBD) by stool DNA. Digestive Disease Week 2010. New Orleans, LA. 2010. 481.
57 Bosch LJ, Neerincx M, Oort FA, et al. Promoter Hypermethylation of PHACTR3, a Potential New Biomaker for Colorectal Cancer Detection. Digestive Disease Week 2009. Chicago, IL. 2009. W1874.
58 Calistri D, Rengucci C, Molinari C, et al. Quantitative fluorescence determination of long-fragment DNA in stool as a marker for the early detection of colorectal cancer. Cellular Oncology. 2009;31(1):11-17. [pmid: 19096146].
59 Cretella M, Kalimutho M, Mannisi E. Detection of L-DNA in stool samples using denaturing high performance liquid chromatography (DHPLC): A novel method for colorectal cancer screening?. Gut. 2009;58(Suppl II).
60 Glockner SC, Dhir M, Yi JM, et al. Methylation of TFPI2 in stool DNA: a potential novel biomarker for the detection of colorectal cancer. Cancer Res. Jun. 1. 2009;69(11):4691-99. [pmid: 19435926].
61 Hellebrekers DM, Lentjes MH, van den Bosch SM, et al. GATA4 and GATA5 are potential tumor suppressors and biomarkers in colorectal cancer. Clin Cancer Res. Jun. 15. 2009;15(12):3990-97. [pmid: 19509152].
62 Kim MS, Louwagie J, Carvalho B, et al. Promoter DNA methylation of oncostatin m receptor-beta as a novel diagnostic and therapeutic marker in colon cancer. PLoS ONE [Electronic Resource]. 2009;4(8):e6555. [pmid: 19662090].
63 Mayor R, Casadome L, Azuara D, et al. Long-range epigenetic silencing at 2q14.2 affects most human colorectal cancers and may have application as a non-invasive biomarker of disease. Br J Cancer. May. 19. 2009;100(10):1534-39. [pmid: 19384295].
64 Melotte V, Lentjes MH, van den Bosch SM, et al. N-Myc downstream-regulated gene 4 (NDRG4): a candidate tumor suppressor gene and potential biomarker for colorectal cancer. J Natl Cancer Inst. Jul. 1. 2009;101(13):916-27. [pmid: 19535783].
65 Nagasaka T, Tanaka N, Cullings HM, et al. Analysis of fecal DNA methylation to detect gastrointestinal neoplasia. J Natl Cancer Inst. Sep. 16. 2009;101(18):1244-58. [pmid: 19700653].
66 Zou H, Harrington J, Hussain FT. Stool DNA and occult blood for detection of colorectal cancer: complementrary markers. Digestive Disease Week 2009. Chicago, IL. 2009. T2034.
67 Zou H, Harrington J, Taylor WR. Pan-detection of gastrointestinal neoplasms by stool DNA testing: establishment of feasibility. Digestive Disease Week 2009. Chicago, IL. 2009. T2036.
68 Zou H, Taylor WR, Harrington JJ, et al. High detection rates of colorectal neoplasia by stool DNA testing with a novel digital melt curve assay. Gastroenterology. Feb. 2009;136(2):459-70. [pmid: 19026650].
69 Zou H, Jaing X, Harrington J. Quantitative stool DNA testing for detection of both colorectal cancer and advanced adenoma. Digestive Disease Week 2009. 2009 May 30. Chicago, IL. 2009:T2037.
70 Oberwalder M, Zitt M, Wontner C, et al. SFRP2 methylation in fecal DNA–a marker for colorectal polyps. International Journal of Colorectal Disease. Jan. 2008;23(1):15-19. [pmid: 17639423].
71 Onouchi S, Matsushita H, Moriya Y, et al. New method for colorectal cancer diagnosis based on SSCP analysis of DNA from exfoliated colonocytes in naturally evacuated feces. Anticancer Research. Jan. 2008;28(1A):145-50. [pmid: 18383838].
72 Wang DR, Tang D. Hypermethylated SFRP2 gene in fecal DNA is a high potential biomarker for colorectal cancer noninvasive screening. World J Gastroenterol. Jan. 28. 2008;14(4):524-31. [pmid: 18203283].
73 Abbaszadegan MR, Tavasoli A, Velayati A, et al. Stool-based DNA testing, a new noninvasive method for colorectal cancer screening, the first report from Iran. World J Gastroenterol. Mar. 14. 2007;13(10):1528-33. [pmid: 17461444].
74 Abbaszadegan MR, Velayati A, Tavasoli A, et al. Rapid DNA extraction protocol from stool, suitable for molecular genetic diagnosis of colon cancer. Iranian Biomedical Journal. Jul. 2007;11(3):203-08. [pmid: 18051782].
75 Huang Z, Li L, Wang J. Hypermethylation of SFRP2 as a potential marker for stool-based detection of colorectal cancer and precancerous lesions. Dig Dis Sci. Sep. 2007;52(9):2287-91. [pmid: 17410438].
76 Huang ZH, Li LH, Yang F, et al. Detection of aberrant methylation in fecal DNA as a molecular screening tool for colorectal cancer and precancerous lesions. World J Gastroenterol. Feb. 14. 2007;13(6):950-54. [pmid: 17352030].
77 Leung WK, To KF, Man EP, et al. Detection of hypermethylated DNA or cyclooxygenase-2 messenger RNA in fecal samples of patients with colorectal cancer or polyps. Am J Gastroenterol. May. 2007;102(5):1070-76. [pmid: 17378912].
78 Onouchi S, Matsushita H, Nomura S, et al. PCR-based assessment of the recovery rate of exfoliated colonocytes or cancer cells from fecal samples depends on the storage conditions after defecation. Journal of Gastrointestinal & Liver Diseases. Dec. 2007;16(4):369-72. [pmid: 18193116].
79 Rennert G, Kislitsin D, Brenner DE, et al. Detecting K-ras mutations in stool from fecal occult blood test cards in multiphasic screening for colorectal cancer. Cancer Letters. Aug. 18. 2007;253(2):258-64. [pmid: 17349741].
80 Zou H, Harrington J, Rego RL, et al. A novel method to capture methylated human DNA from stool: implications for colorectal cancer screening. Clin Chem. 2007;2007(9):1646-51. [pmid: 17712002].
81 Zhang W, Bauer M, Croner RS, et al. DNA stool test for colorectal cancer: hypermethylation of the secreted frizzled-related protein-1 gene. Dis Colon Rectum. 2007;50(10):1618-26. [pmid: 17762966].
82 Jin YM, Li BJ, Qu B, et al. BRAF, K-ras and BAT26 mutations in colorectal polyps and stool. World J Gastroenterol. Aug. 28. 2006;12(32):5148-52. [pmid: 16937524].
83 Zou H, Harrington JJ, Klatt KK, et al. A sensitive method to quantify human long DNA in stool: relevance to colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1115-19. [pmid: 16775168].
84 Lenhard K, Bommer GT, Asutay S, et al. Analysis of promoter methylation in stool: a novel method for the detection of colorectal cancer. Clini Gastroenterol Hepatol. Feb. 2005;3(2):142-49. [pmid: 15704048].
85 Matsushita H, Matsumura Y, Moriya Y, et al. A new method for isolating colonocytes from naturally evacuated feces and its clinical application to colorectal cancer diagnosis. Gastroenterology. Dec. 2005;129(6):1918-27. [pmid: 16344060].
86 Petko Z, Ghiassi M, Shuber A, et al. Aberrantly methylated CDKN2A, MGMT, and MLH1 in colon polyps and in fecal DNA from patients with colorectal polyps. Clin Cancer Res. Feb. 1. 2005;11(3):1203-09. [pmid: 15709190].
87 Belshaw NJ, Elliott GO, Williams EA, et al. Use of DNA from human stools to detect aberrant CpG island methylation of genes implicated in colorectal cancer. Cancer Epidemiol Biomarkers Prev. Sep. 2004;13(9):1495-501. [pmid: 15342451].
88 Calistri D, Rengucci C, Lattuneddu A, et al. Detection of colorectal cancer by a quantitative fluorescence determination of DNA amplification in stool. Neoplasia (New York). Sep. 2004;6(5):536-40. [pmid: 15548362].
89 Leung WK, To KF, Man EP, et al. Detection of epigenetic changes in fecal DNA as a molecular screening test for colorectal cancer: a feasibility study. Clinical Chemistry. Nov. 2004;50(11):2179-82. [pmid: 15502094].
90 Muller HM, Oberwalder M, Fiegl H, et al. Methylation changes in faecal DNA: a marker for colorectal cancer screening?. Lancet. Apr. 17. 2004;363(9417):1283-85. [pmid: 15094274].
91 Wan J, Zhang ZQ, You WD, et al. Detection of K-ras gene mutation in fecal samples from elderly large intestinal cancer patients and its diagnostic significance. World J Gastroenterol. Mar. 1. 2004;10(5):743-46. [pmid: 14991952].
92 Boynton KA, Summerhayes IC, Ahlquist DA, et al. DNA integrity as a potential marker for stool-based detection of colorectal cancer. Clinical Chemistry. Jul. 2003;49(7):1058-65. [pmid: 12816901].
93 Ito Y, Kobayashi S, Taniguchi T, et al. Frequent detection of K-ras mutation in stool samples of colorectal carcinoma patients after improved DNA extraction: comparison with tissue samples. International Journal of Oncology. Jun. 2002;20(6):1263-68. [pmid: 12012008].
94 Koshiji M, Yonekura Y, Saito T, et al. Microsatellite analysis of fecal DNA for colorectal cancer detection. Journal of Surgical Oncology. May. 2002;80(1):34-40. [pmid: 11967905].
95 Nishikawa T, Maemura K, Hirata I, et al. A simple method of detecting K-ras point mutations in stool samples for colorectal cancer screening using one-step polymerase chain reaction/restriction fragment length polymorphism analysis. Clinica Chimica Acta. Apr. 2002;318(1-2):107-12. [pmid: 11880119].
96 Traverso G, Shuber A, Levin B, et al. Detection of APC mutations in fecal DNA from patients with colorectal tumors. New England Journal of Medicine. Jan. 31. 2002;346(5):311-20. [pmid: 11821507].
97 Traverso G, Shuber A, Olsson L, et al. Detection of proximal colorectal cancers through analysis of faecal DNA. Lancet. Feb. 2. 2002;359(9304):403-04. [pmid: 11844514].
98 Doolittle BR, Emanuel J, Tuttle C, et al. Detection of the mutated K-Ras biomarker in colorectal carcinoma. Exp Mol Pathol. Jun. 2001;70(3):289-301. [pmid: 11418008].
99 Rengucci C, Maiolo P, Saragoni L, et al. Multiple detection of genetic alterations in tumors and stool. Clin Cancer Res. Mar. 2001;7(3):590-93. [pmid: 11297253].
100 Kalimutho M, Del Vecchio BG, Cretella M, et al. A simplified, non-invasive fecal-based DNA integrity assay and iFOBT for colorectal cancer detection. Int J Colorectal Dis. 2011. Jan. 12. [pmid: 21225430].
101 Calistri D, Rengucci C, Casadei GA, et al. Fecal DNA for noninvasive diagnosis of colorectal cancer in immunochemical fecal occult blood test-positive individuals. Cancer Epidemiol Biomarkers Prev. Oct. 2010;19(10):2647-54. [pmid: 20929882].
102 Puig P, Urgell E, Capella G, et al. A highly sensitive method for K-ras mutation detection is useful in diagnosis of gastrointestinal cancer. Int J Cancer. Jan. 1. 2000;85(1):73-77. [pmid: 10585586].
103 Soares-Weiser K, Burch J, Duffy S, et al. Diagnostic accuracy and cost-effectiveness of faecal occult blood tests (FOBT) used in screening for colorectal cancer: a systematic review. CRD Report 362007. Centre for Reviews and Dissemination (CRD). 2007.
104 Chung DC. Stool DNA testing and colon cancer prevention: another step forward. Ann Intern Med. Oct. 7. 2008;149(7):50918838724-510. [pmid: 18838731].
105 Sun F, Bruening W, Erinoff E, et al. Evaluation Frameworks and Assessment of Analytic Validity. AHRQ Publication No. 11-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
106 Schroy PC III, Heeren TC. Patient perceptions of stool-based DNA testing for colorectal cancer screening. Am J Prev Med. 2005;2005(2):208-14. [pmid: 15710277].
107 Berger BM, Schroy PC III, Rosenberg JL, et al. Colorectal cancer screening using stool DNA analysis in clinical practice: early clinical experience with respect to patient acceptance and colonoscopic follow-up of abnormal tests. Clin Colorectal CanCer. Jan. 2006;5(5):338-43. [pmid: 16512992].
108 Schroy PC III, Lal S, Glick JT, et al. Patient preferences for colorectal cancer screening: how does stool DNA testing fare?. Am J Manag Care. 2007;13(6):393-400. [pmid: 17620034].
109 Marshall DA, Johnson FR, Phillips KA, et al. Measuring patient preferences for colorectal cancer screening using a choice-format survey. Value Health. Sep. 2007;10(5):415-30. [pmid: 17888107].
110 Marshall DA, Johnson FR, Kulin NA, et al. How do physician assessments of patient preferences for colorectal cancer screening tests differ from actual preferences? A comparison in Canada and the United States using a stated-choice survey. Health Econ. Dec. 2009;18(12):1420-39. [pmid: 19191268].
111 Niv Y. Fecal occult blood test—the importance of proper evaluation. J Clin Gastroenterol. Aug. 1990;12(4):393-5. [pmid: 2398247].
112 Fleisher M, Winawer SJ, Zauber AG, et al. Accuracy of fecal occult blood test interpretation. National Polyp Study Work Group. Ann Intern Med. May. 15. 1991;114(10):875-6. [pmid: 2014949].
113 Selinger RR, Norman S, Dominitz JA. Failure of health care professionals to interpret fecal occult blood tests accurately. Am J Med. Jan. 2003;114(1):64-67. [pmid: 12543293].
114 Anwar R. Screening for colorectal cancer in the UK. Dig Liver Dis. Apr. 2006;38(4):279-82. [pmid: 16549395].
115 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. Jun. 6. 2006;144(11):850-5. [pmid: 16754927].
116 Medical Services Advisory Committee. Faecal occult blood testing for population health screening. Canberra. Medical Services Advisory Committee (MSAC). 2004.
117 Lansdorp-Vogelaar I, Kuntz KM, Knudsen AB, et al. Stool DNA testing to screen for colorectal cancer in the Medicare population: a cost-effectiveness analysis. Ann Intern Med. Sep. 21. 2010;153(6):368-77. [pmid: 20855801].
118 Institute of Medicine. Generating Evidence for Genomic Diagnostic Test Development: Workshop Summary. Washington, DC. The National Academies Press. 2011.
119 Exact Sciences. Second-Quarter 2011 Earnings Call. Second-Quarter 2011 Earnings Call. 2011 Aug 2. Madison, WI. Exact Sciences Corporation. 2011.
120 Exact Sciences. Exact Sciences Investor Update. Exact Sciences Corporation. 2010.
121 Sobhani I, Roudot-Thoraval F, Roperch JP, et al. Should FOBT be replaced by altered DNA in colorectal cancer (CRC) screening?. Gastroenterology. May. 2010;138(5, Suppl 1):S-194.
122 Validation of an Alternative Biological Test to Increase the Dection Sensitivity of a Colon Tumour. (study in progress).
123 Kanaoka S, Hamaya Y, Kuriyama S, et al. Fecal Beta2-Microglobulin and Creatine Kinase B mRNA Assays as a Marker for Colorectal Cancer Screening. Gastroenterology. May. 2011;140(5, Suppl 1):S-414. S-415.
124 Kanaoka S, Yoshida K, Hamaya Y, et al. Fecal RNA testing using quantitative real-time RT-PCR for detecting colorectal cancer and adenoma. Gastronenterology. May. 2010;138(5, Suppl 1):S-188.
125 Kanaoka S, Yoshida K, Hamaya Y, et al. Usefulness of Fecal COX-2, MMP-7 and Snail mRNAs Assay Using Quantitative RT-PCR for Detecting Colorectal Cancer. Gastroenterology. May. 2009;136(5, Suppl 1):A-627.
126 Koga Y, Yasunaga M, Takahashi A, et al. Fecal RNA test using microRNA expressions of exfoliated coloncytes for colorectal cancer screenings. 2011 Apr 2. Orlando, FL. Philadelphia, PA. American Association for Cancer Research. 2011:1819.
127 Wu CW, Dong YJ, Ng SS, et al. Identification of a panel of MicroRNAs in stool screening markers for colorectal cancer. Gastroenterology. May. 2011;140(5, Suppl 1):S-73.
128 Link A, Balaguer F, Shen Y, et al. Fecal microRNAs: novel biomarkers for colon cancer screening. Gastroenterology. May. 2010;138(5, Suppl 1):S-134.
129 Wu CW, Ng SS, Lueng WW, et al. MicroRNAs in stool as screening marker for colorectal cancer. Gastroenterology. May. 2010;138(5, Suppl 1):S-194.
130 Kim MS, Lee J, Sidransky D. DNA methylation markers in colorectal cancer. Cancer Metastasis Rev. Mar. 2010;29(1):181-206. [pmid: 20135198].
131 Ahlquist DA. Can a serum test detect cancer precursor lesions?. Digestive Disease Week. 2011 May 7. Chicago, IL. 2011:Sp224.
132 Weiss G, Rosch T. Potential of a new blood test for colorectal cancer screeing—the Septin 9 Gene Biomarker. European Oncology. 2009;6(1):51-54.
133 Wang H, Schiller DE, Tso V, et al. A new and highly sensitive screening tool for colorectal adenoatous polyps using a spot urine metabolomics test. Gastroenterology. May. 2011;140(5, Suppl 1):S-420.