# Peer Reviewers

Durado Brooks, M.D., M.P.H.

Director, Prostate and Colorectal Cancers

American Cancer Society

Atlanta, GA

Carrie Klabunde, Ph.D.

Epidemiologist, Health Services and Economics Branch, Applied Research Program, Division of Cancer Control and Population Sciences

National Cancer Institute

Bethesda, MD

Bernard Levin, M.D.

Professor Emeritus

The University of Texas M. D. Anderson Cancer Center

Houston, TX

David Lieberman, M.D., F.A.C.G.

Professor of Medicine, Division of Gastroenterology, OHSU

Chief of Division OHSU/ VAMC

Portland, OR

Paul Pinsky, Ph.D.

Division of Cancer Prevention

National Cancer Institute

Bethesda, MD