# Methods

The Agency for Healthcare Research and Quality (AHRQ) requested a comparative effectiveness review on the use of fecal DNA analysis in screening for CRC as part of its Effective Health Care (EHC) program. The Oregon Evidence-based Practice Center (EPC) was assigned this review and subsequently established a review team, developed a review protocol, conducted the review, and drafted a report summarizing the review's findings.

## Topic Development and Refinement

The Oregon EPC developed this topic for consideration for a systematic review based on a public nomination submitted to the AHRQ EHC program. For the topic development phase, we prepared a topic brief that provided a scan of the evidence and contextual details addressing the EHC program prioritization criteria. The topic prioritization group from the EHC program evaluated the appropriateness, importance, feasibility, desirability, and potential and relative value and recommended a Comparative Effectiveness Review.38

The proposed Key Questions and the Analytic Framework were posted for public comment on the EHC Program website from February 7 through March 7, 2011 before finalizing. During the public review of the proposed Key Questions, several individuals expressed concern about the optimal timing of this review due to the development and ongoing research on a new fecal DNA screening test. Despite these comments, it was felt that a review would still be helpful to stakeholders before the availability of newer testing. No changes to the KQs or Analytic Framework were made on the basis of the public comments. After developing the proposed review protocol, a Technical Expert Panel (TEP) was convened to help refine the draft protocol. The TEP consisted of experts in the areas of gastroenterology, cancer screening, stool-based testing (fecal DNA and FIT), genetic testing, and systematic review methods. Discussions among the EPC, AHRQ, and TEP members occurred during two teleconferences and via e-mail. In addition, input from the TEP during the conduct of the review was sought to help address content about the evolution of fecal DNA testing. The TEP was not otherwise involved in the conduct of the review or writing of the report.

## Analytic Framework

We developed an Analytic Framework to illustrate the relationship between the Key Questions addressed in our review (Figure 1).

Figure 1 Analytic framework of the benefits and harms of fecal DNA testing in screening for colorectal cancer

This figure depicts how the Key Questions in this report inter-relate using an Analytic Framework convention. The figure illustrates how screening with fecal DNA testing among asymptomatic adults at average risk for colorectal cancer may result in improved detection of colorectal cancer and/or precancerous lesions, as well as improved health outcomes such as decreased colorectal cancer mortality, decreased all-cause mortality, and decreased colorectal cancer incidence. The figure also illustrates that harms may occur from screening, and management or treatment of cancer or precancerous lesions.

## Literature Search Strategy

We performed comprehensive literature searches in the following databases: MEDLINE, Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, Database of Abstracts of Reviews of Effects, and the Health Technology Assessments Database. Searches were limited to English language studies published, from January 2000 through August 11, 2011. See Appendix A for complete search string. Searches of these databases were supplemented with manual searching of reference lists of relevant review articles and suggestions made by TEP members.

In addition to a search of the published literature, we also performed a focused search of the grey literature. For the purposes of this review, grey literature comprised information that was not controlled by commercial publishing, including: unpublished data from recent (2009–2011) conference abstracts (e.g., American Association for Cancer Research, American Association for Clinical Chemistry, American College of Gastroenterology, American Society of Clinical Oncology, Digestive Disease Week, Gastrointestinal Cancers Symposium), regulatory documents (e.g., FDA Medical and Statistical Reviews; Authorized Medicines for the European Union), proprietary data submitted via manufacturer, and information regarding ongoing and future research via clinical trial registry entries (e.g., ClinicalTrials.gov and WHO Clinical Trials). Additional unpublished literature was sought via a Scientific Information Packet (SIP) request to LabCorp. Literature from Exact Sciences were provided by TEP members.

The results of the searches were downloaded and imported into version 11.0.1 of Reference Manager (Thomson Reuters, New York, NY), a bibliographic management database.

## Process for Study Selection

The results of the electronic literature searches, hand searches, and TEP-suggested literature were screened using a two-step process for study selection. Abstracts were screened independently by two reviewers against a set of a priori inclusion criteria developed in consultation with the TEP (Table 2). We restricted included populations to persons at average-risk for CRC. Although we excluded case-control studies and cohorts in high-risk patients as this study design and distorted selection of patients has been shown to overestimate sensitivity,39,40 because of a paucity of included studies to address Key Questions 1 and 2, we do acknowledge these excluded case-control or cohort studies in high-risk patients in a separate table. We included studies conducted in any setting, but limited the acceptable studies for analytic validity to tests currently available to patients. We also limited the literature to English language only published in 2000 or later, which our TEP confirmed would capture the relevant literature. Full-text articles of abstracts meeting inclusion criteria were retrieved and dual-reviewed against the inclusion criteria. Disagreements were resolved through consultation with a third reviewer. Reviewers were not masked to the study authors, institution, or journal. Excluded articles can be found with the reason for exclusion in Appendix B.

Table 2 Inclusion criteria

Category | Inclusion Criteria
Population | KQs 1–6: Adults ≥40 years old at average risk for CRC. We excluded populations exclusively in adults who are at high-risk for CRC and those diagnosed with CRC. Persons at high risk for CRC include persons with a strong family history of CRC including syndrome-related elevated risks (e.g., FAP, HNPCC) and persons referred to diagnostic colonoscopy for abnormal screening test results.
Interventions | KQs 1–6: Fecal assays intended to screen for CRC, through early cancer or precancerous lesions identification by DNA testing including genotyping, gene-expression measurement, and/or methylation detection. Fecal DNA tests may be performed alone or in combination with other CRC-screening tests. KQ 4: Tests will be limited to those that are currently available to patients, because the assay technology has changed significantly over time.
Comparator | KQ 1: No screening or another established CRC-screening modality (colonoscopy, FOBT [high-sensitivity or traditional], FIT, flexible sigmoidoscopy, barium enema, or CT colonography). KQ 2: For absolute test performance: colonoscopy alone or supplemented by another test. For relative test performance: any established CRC-screening modality. KQ 5: Any established CRC-screening modality.
Outcomes | KQ 1: CRC incidence (or advanced neoplasia incidence if CRC incidence is not reported), all-cause mortality, and CRC-specific mortality. KQs 2 & 3: Absolute or relative test-performance measures, including sensitivity, specificity, PPV, NPV, or relative detection rate: For detection of CRC (adenocarcinoma, carcinoma in situ). For adenomas (any histology). For advanced neoplasia, which is a composite outcome including adenocarcinoma, adenomas with high grade dysplasia or villous histology, and adenomas 1 cm or greater in diameter. KQ 4: Analytic sensitivity (lower limit of detection), analytic specificity, and reproducibility. KQ 5: Any self-reported or objective measures of patient acceptability of or patient adherence to fecal-DNA screening. KQ 6: Any reported harms, including test inaccuracy (i.e., false–positive or false–negative results), and negative psychological, ethical, legal, or social consequences.
Time Period | KQs 1–6: 2000–present.
Setting | KQs 1–6: All settings.
Study Geography | KQs 1–6: All locations.
Publication Language | KQs 1–6: English only.
Study Design | KQs 1–2: Systematic review, randomized or nonrandomized controlled trial, prospective or retrospective cohort, diagnostic accuracy studies (excluding case-control studies). KQs 3–6: Any study design.
Followup Duration | KQs 1–6: We did not exclude studies based on duration of followup. Timing of application of reference-standard testing was considered as part of the quality assessment.
Sample Size | KQs 1–6: We did not exclude studies based on sample size alone.

CRC=colorectal cancer; CT colonography=computed tomographic colonography; FAP=familial adenomatous polyposis; FIT= fecal immunochemical test; FOBT= fecal occult blood test; HNPCC=hereditary nonpolyposis colorectal cancer; NPV=negative predictive value; PPV=positive predictive value

Grey literature findings were initially reviewed by one reviewer and confirmed by a second reviewer. While grey literature sources were selected using the same eligibility criteria used for the published literature, the timeframe for conference abstracts was condensed to 2009-2011.

## Data Abstraction and Data Management

Data from all included studies were abstracted into standardized evidence tables in Microsoft Excel by one reviewer and checked for accuracy and completeness by a second reviewer. Separate abstraction forms were created for key questions related to clinical utility/validity, analytic validity, and acceptability/adherence. The following information was extracted from each study, where applicable: author identification, year of publication, source of study funding, study design characteristics, recruitment setting/patient-inclusion criteria, sample size, and setting; important study population characteristics (e.g., age, race, sex); and fecal DNA test and comparator test (reference standard) characteristics, and all relevant outcomes. We recorded details relevant to the technical specification of the fecal DNA assay being conducted, including the gene mutations/expression analyzed, the assay characteristics and laboratory setting, and the technique used for sample analysis.

For excluded case-control or cohort studies in high-risk patients, we abstracted the markers examined, the study aim, the sample sizes, and outcomes. A higher-level summary of these studies is included in an excluded studies table.

## Individual Study Quality Assessment

To assess the methodological quality of included studies, we applied the study design-specific quality criteria of the U.S. Preventive Services Task Force.41 We supplemented these quality criteria with methods from the Evaluation of Genomic Applications in Practice and Prevention Working Group (specific to genetic testing),42 the Newcastle Ottawa Scale (specific to cohort studies),43 and the QUADAS criteria (specific to diagnostic accuracy studies).44 Two independent reviewers assigned a quality rating of the internal validity for each study. Disagreements were resolved by discussion and consensus, or through consultation with a third reviewer. A rating of “good,” “fair,” or “poor” was assigned by using the predefined criteria for each study design. Good-quality studies generally met all of the study design-specific quality criteria. Fair-quality studies did not meet all the criteria, but did not have any fatal flaws in study design. Poor-quality studies had significant flaws or lack of reporting that imply bias, affecting interpretation of study results. No articles were excluded for quality reasons.

## Data Synthesis

We conducted qualitative syntheses of study results for each key question with included studies. Due to limited number of studies included for each key question and clinical differences amongst studies, we did not conduct meta-analysis of results. For qualitative syntheses, we evaluated and summarize clinical and methodological characteristics of included studies, these included: number and characteristics of study participants, settings in which the study was conducted, specific fecal DNA test evaluated (and important test characteristics), outcomes assessed and statistical considerations of reported results. In our qualitative synthesis we also evaluated and summarize important internal (quality) and external (applicability) of studies, and how the validity affected confidence in interpretation of results. For details on quality and applicability please Individual Study Quality Assessment (above) and Applicability (below) sections. Study results and limitations are also summarized in tables for easy comparison across studies.

## Grading the Strength of Evidence

The strength of evidence for primary outcomes was graded using the standard process of the Evidence-based Practice Centers as outlined in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.45 The grade was based on four major domains: risk of bias, consistency, directness, and precision of the evidence. Grades were assigned for the bodies of evidence pertaining to each primary outcome: high, moderate, low, and insufficient (Table 3).45

Table 3 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit a conclusion.

## Applicability

We also assessed the applicability of studies. Judgments of applicability for each outcome were performed separately from assessments of the other domains of strength of evidence, as recommended.46 Factors in individual studies that might affect applicability were abstracted, particularly including factors related to the populations studied (e.g., how highly selected they were [what portion of those eligible were included], how they were recruited) and if the fecal DNA assay is currently available or not (or how similar is the assay to currently available fecal DNA assays).

## Peer Review and Public Comments

A draft of this review was circulated to eight expert reviewers on August 1, 2011. In addition to this formal expert review process, a draft of this report was posted for public comment from August 1 to August 29, 2011. Members of the TEP were invited to review this draft and submit comments during public posting of this report. We subsequently made revisions based on reviewer comments and an updated literature search.