# Introduction

## Background

### Prevalence and Disease Burden

Colorectal cancer (CRC) is the third most common cancer in men and women, with more than 141,000 new cases expected in the United States (US) in 2011. Approximately 50,000 deaths from CRC are expected to occur in 2011, making CRC the third leading cause of cancer deaths in the United States.1 Survival largely depends on tumor stage at the time of diagnosis. Patients with localized disease at diagnosis have a 5-year survival rate of 90 percent. However, 5-year survival drops to 69 percent for those diagnosed with regionalized disease (cancer spread to regional lymph nodes) and to 12 percent for those with distantly metastasized disease.2 Incidence and mortality are 35 to 40 percent higher in men than women, and are highest in African American men and women, who have 20 percent greater incidence and 45 percent greater mortality than White patients.1

Incidence and mortality rates for CRC have declined over the past two decades.3,4 This decrease has been partially attributed to the use of CRC screening tests that allow for early detection and treatment of cancer or precancerous colorectal polyps. Individuals at increased risk for developing CRC include those over 50 years of age and those with a history of inflammatory bowel disease, family history of the disease, or inherited familial syndromes such as familial adenomatous polyposis or hereditary non-polyposis CRC.1 Lifestyle factors have also been linked to an individual's risk of developing CRC, including a diet high in red or processed meats, lack of exercise, smoking, heavy alcohol use, being overweight, and having type 2 diabetes.1

### Adenoma to Colorectal Cancer Progression

CRC usually develops over a period of 10 to 15 years with the cancer beginning as a precancerous lesion, most commonly a neoplastic polyp, although flat adenomas are increasingly recognized as an important precursor for CRC.5,6 While neoplastic or adenomatous polyps can develop into cancers, fewer than 10 percent will eventually progress to cancer.1 In general, larger adenomas and those with greater dysplasia are more likely to progress to cancer.7 Advanced adenomas is a composite term used to describe precancerous lesions most likely to progress into cancer. Although there is some variation in the exact definition, advanced adenomas generally refer to adenomas 1 cm or greater, with villous components (tubulovillous or villous), or with high-grade or severe dysplasia.

Molecular events are involved in the initiation, promotion, and progression of CRC on many levels, including interactions between the patient's inherited (germ-line) genome and the tumor (somatic) genome.8 Progressive genomic instability in colorectal tissues gives rise to cancer due to accumulating genetic alterations (including gene mutations and amplifications) and epigenetic alterations (including aberrant DNA methylation leading to gene inactivation) that transform healthy cells into carcinoma cells.7 On the molecular level, there is a progression of specific genetic or epigenetic changes that lead to altered functions of proto-oncogenes and tumor suppressor genes that accompany cancer's progression from adenomatous polyp to invasive cancer.8 These genetic and epigenetic changes are the basis for the role of fecal DNA testing in the early detection of CRC.

### Screening of Colorectal Cancer

#### Rationale and current practice

Multiple tests are clinically used to screen for CRC, these include stool based tests (e.g., guaiac based or immunochemical based fecal occult blood testing), endoscopy (e.g., flexible sigmoidoscopy or colonoscopy), and imaging tests (e.g., double contrast barium enema or CT colonography). The decrease in CRC incidence and mortality over the past two decades in the United States corresponds to an increase in self-reported screening rates from less than 25 percent in the 1980s to about 52 percent in 2002 and about 65 percent in 2010.^1,3^ Despite increases in CRC screening over time, screening rates remain below optimal. Multiple patient, clinician, and health-care delivery factors have been found to negatively influence CRC screening, including low socioeconomic or educational status, lack of physician recommendation, and lack of insurance or limited access to health care.9

Most organizations agree that any CRC screening is better than no screening, and that the age to begin screening in adults at average-risk for CRC is 50 years old. Currently, most U.S. guideline organizations, including the U.S. Preventive Services Task Force (USPSTF), agree that the recommended options in screening for CRC include: colonoscopy every 10 years; annual high-sensitivity guaiac fecal occult blood testing (FOBT) or fecal immunochemical testing (FIT); and flexible sigmoidoscopy every 5 years with or without fecal blood testing (FOBT or FIT).10,11

Some disagreement occurs between guideline organizations about screening interventions with less evidence to support their use. These tests include: computerized tomography (CT) colonography, double contrast barium enema (DCBE), and fecal or stool-based DNA testing.10 In 2008, the USPSTF found that evidence was insufficient to recommend fecal DNA testing for CRC screening based on a systematic review of new and established CRC screening modalities.5,11 However, the American Cancer Society (ACS), the U.S. Multi-Society Task Force (MSTF) on Colorectal Cancer, and the American College of Radiology (ACR) collectively recommended fecal DNA testing as an alternative screening method. This discrepancy between recommendations appears to be due to differences in evidence considered. The ACS-MSTF-ACR recommendation was based a lower threshold of evidence than that of the USPSTF.12 While the American College of Gastroenterology recognized that fecal DNA testing may offer an alternative form of CRC screening, they state that the preferred forms of screening include colonoscopy and FIT, noting the very limited evidence for fecal DNA testing.13

#### Evolution of fecal DNA testing for colorectal cancer screening

Unlike other stool-based screening tests that are designed to detect hemoglobin, fecal DNA tests are designed to detect molecular abnormalities in cancer or precancerous lesions that are shed into the stool. Molecular abnormalities in CRC that have served as the basis for screening tests have focused on three major genetic mechanisms: chromosomal instability due to abnormalities in mutational hotspots like APC, KRAS, and TP53; microsatellite instability (MSI) due to loss of function of mismatch repair genes that can result in accumulation of errors within the DNA sequence called microsatellites; and DNA methylation, an epigenetic alteration, in which promoter sites of genes are hypermethylated leading to suppression of gene transcription.14 Although the presence of these alterations does not guarantee a progression to cancer, it is thought that these molecular markers can identify the adenomas most likely to develop into cancer, in addition to detecting early stages of CRC.7

Fecal DNA testing to screen for CRC has evolved over time. Some of the most common (and well studied) DNA markers in stool include mutations in APC, KRAS, and TP53; methylation of vimentin, SFRP2, MGMT, MLH1; and measurements of long-DNA integrity and microsatellite instability.15 The feasibility of stool DNA testing was originally demonstrated using a single marker assay for KRAS in the early 1990s. Later work in 2000 led to the development of a panel of markers intended to detect both advanced adenomas and colorectal tumors. Since that time several configurations of multi-marker stool tests have been evaluated. Earlier studies focused on the Wnt signaling pathway and microsatellite instability, but these initial studies proved less successful than anticipated. More recently, studies have incorporated the detection of methylated markers, in recognition that gene hypermethylation is a more common pathway in CRC than previously understood.14 Based on our audit of initial validation studies, the most commonly evaluated methylated markers appear to be vimentin and SFRP2. Other potentially useful methylated gene targets for fecal DNA testing include TFPI2 and NDRG4, which are both tumor suppressor genes.16 Due to the molecular heterogeneity of CRC, potential screening tests have generally considered a panel of markers rather than a single marker in an attempt to maximize clinical sensitivity.17 Industry now believes that they have designed panels of markers that cover 100 percent of the target lesions at the tissue level, as compared to only 67 percent of screen-relevant neoplasms when the tissue samples were examined with the first generation of available testing.18

In addition to improvements in relevant marker identification, there have also been significant technological advances in the past several years to allow for improved detection of molecular abnormalities in DNA.16 However, only 0.01 percent of DNA in the feces is of human origin; most fecal DNA is acquired through outside sources including diet and microflora. Therefore, isolating and detecting target human DNA from the stool presents a challenge for fecal DNA test methodologies.19 Assay development has had to focus on improving the analytic sensitivity (or lower limit of detection) of test methodology and technology. Techniques have been developed to better preserve stool DNA (e.g., buffer to stabilize DNA) and extract DNA from stool. In addition, techniques to enrich target DNA by selective capture from stool followed by digital or emulsion PCR have been developed (e.g., BEAMing and digital melt curve analysis) and seem promising in improving assay sensitivity.16,18

Thus far a single company, Exact Sciences, has been the major developer and licensor of fecal DNA testing in the United States. To date, only two fecal DNA tests have been commercially available. PreGen Plus™ was based on the first developed prototype (by Exact Sciences) and was available from 2003 to 2008 from LabCorp. Most recently, Exact Science has licensed technology to LabCorp, who manufactures and markets ColoSure™, the only commercially available test in the United States (Table 1a and b). The prototype and the previously available test PreGen Plus included the same 23 molecular markers, whereas the newer versions only include methylation of vimentin plus or minus an assay for DNA integrity. Thus, the currently available test ColoSure shares no markers with the previously available test. In addition to this evolution in the composition of the test there have also been advances in pre-analytic and analytic technologies. Pre-analytic factors include specimen collection, processing, handling, and delivery to testing site. Analytic factors include test methods and performance of procedures, and monitoring and verification of accuracy and reliability of test results. The major pre-analytic advance was the addition of DNA stabilization buffer at the time of stool collection, which prevents the degradation of DNA while the stool is in transport and storage. The major analytic advances included the use of technologies to isolate human DNA targets that improve the analytic sensitivity or lower limit of detection of these assays.

Table 1a Development of fecal DNA testing for colorectal cancer screening: Market availability and test details

Market Availability and Test Details | Prototype sDNAversion 1.0 | PreGen Plus™ sDNA version 1.1 | sDNA version 2.0 | sDNA version 2.1 | ColoSure™ sDNA version 2.2 | Next-generation sDNA version 3.0^†^
Availability | Not implemented for clinical use | 2003-2008 as a CLIA regulated LDT | Not implemented for clinical use | Not implemented for clinical use | 2008-present as a CLIA regulated LDT | Not available^‡^
Genetic markers^*^ | 21 point mutations in APC, KRAS, and TP53 one microsatellite instability marker, BAT-26 one Long DNA marker, DNA Integrity Assay (DIA) | Same 23 molecular markers as prototype (sDNA 1.0) | Vimentin methylation Point mutations in APC and KRAS | Vimentin methylation DIA | Vimentin methylation | NDRG4 and BMP3 methylation 7 point mutations KRAS exon 2
Non-genetic measures | None | None | None | None | None | Fecal Immunochemical Test (FIT)
Advances in pre-analytic factors | Specimen homogenization for target uniformity in aliquots | Stabilizing buffer at time of stool collection | Stabilizing buffer at time of stool collection | Stabilizing buffer at time of stool collection | Stabilizing buffer at time of stool collection | Stabilizing buffer at time of stool collection
Advances in analytic factors | Bead based human DNA target hybrid capture from resolubilized, precipitated total DNA | Gel-capture method for isolating DNA targets from resolublized, precipitated total DNA | Bead based human DNA target hybrid capture from resolublized, precipitated total DNA | Bead based human DNA target hybrid capture from resolublized, precipitated total DNA | Bead based human DNA target hybrid capture from resolublized, precipitated total DNA | Direct bead based DNA target hybrid capture from stool homogenate supernatant QuARTS™ target and signal amplification method Multiplexed target assays Automated analytic steps, high through-put

Stool DNA=sDNA; Clinical Laboratory Improvement Amendments=CLIA; Laboratory-developed test= LDT; DNA integrity assay=DIA; Fecal immunochemical test =FIT

* Full information on genes can be found at http://www.ncbi.nlm.nih.gov/gene

† Exact Sciences. Second-Quarter 2011 Earnings Call; 2011 August 2; Madison, WI: Exact Sciences Corporation; 2011.

‡ FDA submission for pre-market approval or clearance planned for late 2012

Table 1b Development of fecal DNA testing for colorectal cancer screening: Evidence

Evidence | Prototype sDNA version 1.0 | | PreGen Plus sDNA version 1.1 | sDNA version 2.0 | sDNA version 2.1 | ColoSure sDNA version 2.2 | Next-generation sDNA version 3.0^†^
Test development and/or initial validation | | Ahlquist 2000^20^ Tagore 2003^21^ Calistri 2003^22^ Brand 2004^23^ Syngal 2006^24^ | Whitney 2004^25^ Olson 2005^26^ | Itzkowitz 2007^27^ | Itzkowitz 2008^28^ | Chen 2005^29^ Itzkowitz 2007^27,§^ Itzkowitz 2008^28,§^ Baek 2009^30,§^ Li 2009^31^ Zou 2010^32^ | Expected 2011-2012
Test validation in target population | Imperiale 2004^33^ Ahlquist 2008^34^ | | | Ahlquist 2008^34^ | | | Expected 2013

Stool DNA =sDNA; Clinical Laboratory Improvement Amendments= CLIA; Laboratory-developed test=LDT; DNA integrity assay=DIA; Fecal immunochemical test =FIT

† Exact Sciences. Second-Quarter 2011 Earnings Call; 2011 August 2; Madison, WI: Exact Sciences Corporation; 2011.

§ Studies addressed multiple markers but included data on vimentin as an individual marker

Only one fecal DNA test for the detection of adenomas and colorectal tumors is currently commercially available. This test, ColoSure is provided by LabCorp as laboratory-developed test (LDT) regulated by the Centers for Medicare and Medicaid Services under the Clinical Laboratory Improvement Amendments (CLIA) of 1988. Marketing for commercially available fecal DNA testing specifies that the test is intended for individuals who are not eligible (either unable or unwilling) for more invasive CRC screening (i.e., colonoscopy, flexible sigmoidoscopy, or CT colonography).35 ColoSure has not obtained clearance or approval from the U.S. Food and Drug Administration (FDA). Currently, there are no fecal DNA tests approved by the FDA for screening or diagnosing of CRC. The FDA has chosen to exercise “enforcement discretion” on LDT testing and historically, the FDA's oversight of genetic testing has been focused on commercial test kits. The FDA, however, is now engaged in dialogue with manufacturers and the public on how it should develop a consistent, reasonable, and fair approach for LDTs so as to ensure safety and promote innovation.36

A new fecal DNA test developed by Exact Sciences is projected to be available in 2012 (Table 1a and b). This test will include a combination of markers (methylation of NDRG4, BMP3; 7 point mutations in KRAS exon 2) and an immunochemical assay for hemoglobin.37 The fecal immunochemical test (FIT), while optimized for this new assay, is similar to other currently available ELISA-based FITs.

Changes in markers and assay technology are extremely important to understand when evaluating the evidence base for fecal DNA testing because over time assays have included different markers and used different technologies, limiting the applicability of the existing evidence base to currently (and soon to be) available testing.

## Scope and Purpose

This topic was nominated to the Agency for Healthcare Research and Quality for its Effective Healthcare (EHC) Program by an organization interested in using a review to develop an evidence-based recommendation statement. This review aims to synthesize the evidence on fecal DNA testing to screen for CRC in average-risk adults.

## Key Questions

Six systematically reviewed questions are addressed in this report. These questions address the clinical utility (evidence for impact on patient health outcomes), clinical validity (diagnostic accuracy for CRC or precancerous lesions), analytic validity, acceptability (and adherence), and harms of fecal DNA testing to screen for CRC.

### Question 1 Clinical utility

What is the effectiveness of fecal DNA testing (alone or in combination with other screening tests) to screen for colorectal cancer in reducing morbidity (colorectal cancer incidence) or mortality (all-cause or CRC-specific)?

### Question 2 Clinical validity

2.1 What are the absolute test-performance characteristics (e.g., sensitivity, specificity) of fecal DNA testing for CRC screening, as compared to colonoscopy?
  a. To detect CRC?
  b. To detect precancerous lesion(s)?
2.2 What is the relative test performance of fecal DNA testing as compared to other established screening modalities in current practice?
  a. To detect CRC?
  b. To detect precancerous lesion(s)?

### Question 3 Interval of Screening

What is the test performance of fecal DNA testing across different screening interval(s)?

### Question 4 Analytic Validity

4.1 What is the analytic validity (analytic sensitivity, specificity, and reproducibility) of currently available fecal DNA assays?
4.2 What are the important analytic and pre-analytic factors that can affect fecal DNA assay validity?

### Question 5 Acceptability of Testing

What is the acceptability and adherence of fecal DNA screening in comparison to other stool-based screening tests, or in comparison to more invasive modalities of screening?

### Question 6 Harms

What are the potential harms of fecal DNA testing?