# Glossary

Absolute test performance: Performance of a test (sensitivity, specificity) when compared to the gold standard
Accuracy: Ability of assay to measure what it purports to measure determined independently by a reference method
Adenoma: Benign tumor from epithelial tissue
Advanced adenomas: Adenomas 1 cm or greater, or with villous components (tubulovillous or villous), or with high-grade or severe dysplasia
Aliquots: A measured portion of a sample taken for analysis
Analytic factors: Test methods and performance of procedures, and monitoring and verification of accuracy and reliability of test results
Analytic sensitivity (lower limit of detection): Ability of assay to detect all true positive specimens, for quantitative tests this is defined as the smallest quantity of a substance that can be reliably detected or quantified
Analytic specificity: Ability present in the sample of assay to measure the target substance when potentially interfering or cross-reacting substances are present in the sample
Analytic validity: An assay's ability to accurately and reliably measure the genotype (or analyte) of interest
Assay: An analysis conducted to verify the presence (and amount) of a substance
Chromosomal instability: The gain or loss of whole chromosomes or fractions of chromosomes
Clinical utility: A test's ability to improve clinical outcomes and the test's usefulness and value it adds to patient management decision-making, compared with current management without genetic testing
Clinical validity: A test's ability to accurately and reliably predict the clinically defined disorder or phenotype of interest
DNA integrity: Potential biomarker for colorectal cancer because DNA shed from cancer cells have been characterized as having longer DNA fragments as compared to DNA shed from non-cancer cells.
Enzyme-linked immunosorbent assay (ELISA): A biochemical technique used to detect the presence of an antibody or an antigen in a sample
Epigenetics: Changes in gene expression caused by mechanisms other than changes in the DNA sequence
Germ-line: Genetic material passed from parents to offspring
Guaiac based fecal occult blood test (FOBT): An assay to detect the presence of hemoglobin in the feces that is not visibly apparent in which feces is applied to a thick piece of paper attached to a thin film coated with guaiac (a phenolic compound)
Immunochemical based fecal occult blood test (FOBT) or fecal immunochemical test (FIT): An assay to detect the presence of hemoglobin in feces that is not visibly apparent in which a fecal sample is collected (e.g., with a brush, probe, stick) and transferred to a test card or slide (dry sampling) or deposited into a liquid buffer (wet sampling). Occult blood is then detected using an antibody specific for human hemoglobin.
Initial test validation: study designed to determine ability and diagnostic accuracy of a test in persons with the target condition (as opposed to validation in the test's intended population); for this report in persons with known CRC or colorectal adenomas; these studies are most often case-control studies in which cases are persons with known CRC or colorectal cancer versus healthy controls
Methylation: The addition of a methyl group
Methylation specific PCR: A method of methylation analysis that uses bisulfite-treated DNA but does not require sequencing
Microsatellite instability: DNA damage due to defects in the normal DNA repair process
Oncogenes: Genes that have the potential to cause cancer
Pre-analytic factors: factors that may affect test performance prior to analysis specimen collection, processing, handling, and delivery to testing site
Proto-oncogenes: A normal gene that may become an oncogene due to mutations or increased expression
Reagent: A substance or mixture for use in chemical analysis or other reactions
Relative test performance: Diagnostic accuracy (sensitivity, specificity) when compared to another test that is not the gold standard
Repeatability: Replication of results when the assay is performed multiple times on a single specimen
Somatic cells: cells of the body excluding reproductive (germ-line) cells
Transcription: the copying of DNA into mRNA in gene expression
Tumor suppressor genes: a gene that protects a cell on the path to cancer
Wnt signaling pathway: a network of proteins in which alterations are associated with carcinogenesis