# Future Research

Future research for fecal DNA testing to screen for CRC should focus on identified evidence gaps. Research to facilitate clinical adoption of fecal DNA testing should focus on the diagnostic accuracy of testing of those tests that are widely available at present or in the near future, as well as the comparative effectiveness of fecal DNA testing versus other best alternative stool-based screening tests (e.g., FIT). Future research to inform the net clinical benefit and optimal intervals for repeated screening will likely be from CISNET's microsimulation models. Analytic validity studies, especially on accuracy and repeatability/reproducibility, should be published or made publically available. More upstream test development should focus on defining the optimum combination of markers and simplifying and automating test procedure without loss of analytic validity to improve throughput and reduce cost.

## Upcoming Studies

Through conversations with our TEP, conference presentations, and information from investment conference telephone calls, we understand that Exact Science is currently developing a new assay, a multi-marker fecal DNA test plus FIT, Cologuard^SM^. This test is expected to be available within the next couple of years. To our knowledge it includes a combination of different markers (two methylation markers, seven mutations in KRAS exon 2) and a FIT, and uses new proprietary technology QuARTS ™ (Table 1a and b).119 Initial validation results which have been presented suggest improved sensitivity for both CRC and large adenomas (85 percent and 64 percent, respectively).120 Initial validation studies are expected to be published in later 2011 and 2012. A large prospective study (DeeP-C) to evaluate Cologuard test performance in average-risk patients for CRC cancer has started to enroll patients as of June 30, 2011 (clinicaltrials.gov identifier: NCT01397747). Results from this prospective study are expected in 2013 to coincide with an application for FDA approval and review for CMS National Coverage Decision of Cologuard to screen for CRC. Other than Cologuard, we did not identify any other forthcoming (widely or commercially available) fecal DNA testing in North America.

Although fecal DNA test development and validation continues to be an active area of research, we found only two upcoming studies, in addition to the Cologuard study, that appear to evaluate tests in clinically relevant populations (asymptomatic screening populations). From our review of relevant conferences, we found numerous abstracts (without full publication of results) on the initial validation of different tests (and different combinations of markers) (Table 4a and 4b). However, we identified one potential study in abstract form that evaluated fecal DNA testing in an asymptomatic screening population.121 In addition to conference abstracts, we searched for upcoming studies in study registries and found an additional study (currently in progress) evaluating the test performance of a fecal DNA test for methylated DNA, Colohybritest.122 This test evaluation, however, is being conducted in asymptomatic persons with a positive FOBT.122

## Other Emerging Genomic Tests

Genetic or genomic tests other than fecal DNA testing were not included in this review. The use of RNA markers in stool has not been as extensively studied as DNA markers, but is a new area of active research. Multiple forms of RNA have been studies as potential cancer biomarkers in fecal samples. These include both messenger RNA (mRNA), which is protein coding, as well as microRNA which are noncoding sequences that affect gene expression. Recent preliminary research presented as meeting abstracts indicates that the most promising mRNA markers may be COX2, MMP7, B2M, CKB, and Snail mRNAs.123-125 Candidate markers for microRNA (miRNA) that been identified in preliminary exploratory research include miR-17-92, miR-18a, miR-20a, miR-21, miR-92, miR-106a, miR-135, and miR-221.^126-129^

In addition to genetic testing in stool samples, the use of DNA or RNA in plasma and serum has also been examined using PCR-based assays that can detect small amount of genetic and epigenetic alterations in circulating tumor DNA.130 The most recent efforts have focused on the detection of methylated DNA , the most widely studied marker is currently SEPT9, this marker is one of the few that has had multiple initial test validation studies.131 Test accuracy based on initial validation studies have varied across independent case-control studies. Preliminary results from a large prospective study (n=7,914) in asymptomatic patients focused on SEPT9 plasma screening are expected to be published in the Summer of 2011.^132^ Research is ongoing to identify additional markers that may add to the sensitivity of detection in plasma and serum samples.130

Finally, the detection of nucleic acid biomarkers of CRC in urine is a new approach with very limited data at this time. For markers to be present in urine some degree of metabolism would be required to clear glomerular filtration and be excreted. Levels of nucleosides (small-fragment metabolic products of DNA) characteristic of CRC and adenomas have been found in urine and have been proposed as a mechanism to discriminate patients with CRC from controls.17,133