# List of Excluded Studies

1 Anderson WF, Guyton KZ, Hiatt RA, et al. Colorectal cancer screening for persons at average risk. J Natl Cancer Inst. Aug. 7. 2002;94(15):1126-33. [pmid: 12165637]. Study design.
2 Belshaw NJ, Elliott GO, Williams EA, et al. Use of DNA from human stools to detect aberrant CpG island methylation of genes implicated in colorectal cancer. Cancer Epidemiol Biomarkers Prev. Sep. 2004;13(9):1495-501. [pmid: 15342451]. Population.
3 Calistri D, Rengucci C, Casadei GA, et al. Fecal DNA for noninvasive diagnosis of colorectal cancer in immunochemical fecal occult blood test-positive individuals. Cancer Epidemiol Biomarkers Prev. Oct. 2010;19(10):2647-54. [pmid: 20929882]. Population.
4 Capella G. Is fecal DNA testing superior to fecal occult-blood testing for colorectal cancer screening?. Nat Clin Pract Oncol. May. 2005;2(5):234-35. [pmid: 16264954]. Study design.
5 Ferretti G, Bria E, Carlini P, et al. Is stool DNA multitarget testing an unreliable strategy for colorectal cancer screening?. Gut. Jun. 2005;54(6):891. [pmid: 15888808]. Study design.
6 Frossard JL, de Peyer R. Fecal DNA for colorectal-cancer screening. N Engl J Med. Mar. 31. 2011;352(13):1384-85. [pmid: 15800239]. Study design.
7 Hardison DM, Shuber AP. Stool DNA: a viable option for colorectal cancer screening. Gastroenterology. Dec. 31. 2005;129(6):2128-9. [pmid: 16344091]. Study design.
8 Itzkowitz S, Brand R, Jandorf L, et al. A simplified, noninvasive stool DNA test for colorectal cancer detection. Am J Gastroenterol. Nov. 2008;103(11):2862-70. [pmid: 18759824]. Lack of appropriate comparator.
9 Kalimutho M, Del Vecchio BG, Cretella M, et al. A simplified, non-invasive fecal-based DNA integrity assay and iFOBT for colorectal cancer detection. Int J Colorectal Dis. 2011. Jan. 12. [pmid: 21225430]. Population.
10 Kato I, Badsha KZ, Land S, et al. DNA/RNA markers for colorectal cancer risk in preserved stool specimens: a pilot study. Tumori. Nov. 2009;95(6):753-61. [pmid: 20210241]. Lack of appropriate comparator, Analytic validity not vimentin methylation.
11 Laboratory Corporation of America. Technical Review: ColoSure™, A Stoll DNA-based Colorectal Cancer Screeninng Test. Laboratory Corporation of America. 2008. Study design.
12 Leung WK, To KF, Man EP, et al. Detection of epigenetic changes in fecal DNA as a molecular screening test for colorectal cancer: a feasibility study. Clin Chem. Nov. 2004;50(11):2179-82. [pmid: 15502094]. Population.
13 Muller HM, Oberwalder M, Fiegl H, et al. Methylation changes in faecal DNA: a marker for colorectal cancer screening?. Lancet. Apr. 17. 2004;363(9417):1283-85. [pmid: 15094274]. Population.
14 Nechvatal JM, Ram JL, Basson MD, et al. Fecal collection, ambient preservation, and DNA extraction for PCR amplification of bacterial and human markers from human feces. J Microbiol Methods. Feb. 2008;72(2):124-32. [pmid: 18162191]. Analytic validity not vimentin methylation.
15 Ned R, Melillo S, Marrone M. Fecal DNA testing for Colorectal Cancer Screening: the ColoSure™ test. PLoS Currents: Evidence on Genomic Tests. 2011. [pmid: 21487548]. Study design.
16 Olson J, Whitney DH, Durkee K, et al. DNA stabilization is critical for maximizing performance of fecal DNA-based colorectal cancer tests. Diagn Mol Pathol. Sep. 2005;14(3):183-91. [pmid: 16106201]. Test not currently available.
17 Puig P, Urgell E, Capella G, et al. A highly sensitive method for K-ras mutation detection is useful in diagnosis of gastrointestinal cancer. Int J Cancer. Jan. 1. 2000;85(1):73-77. [pmid: 10585586]. Population.
18 Ransohoff DF. Fecal DNA tests for colorectal cancer. N Engl J Med. Jun. 13. 2003;346(24):1912-13. [pmid: 12063379]. Study design.
19 Rennert G, Kislitsin D, Brenner DE, et al. Detecting K-ras mutations in stool from fecal occult blood test cards in multiphasic screening for colorectal cancer. Cancer Letters. Aug. 18. 2007;253(2):258-64. [pmid: 17349741]. Population.
20 Stephenson J. Experimental colon cancer test appears to hold promise. JAMA. Nov. 22. 2000;284(20):2584-29. [pmid: 11086349]. Study design.
21 Worthley DL, Cole SR, Young GP. Fecal DNA for colorectal-cancer screening. N Engl J Med. Nov. 22. 2000;352(13):1384-85. [pmid: 15803528]. Study design.
22 Young GP, Worthley DL. Screening with a fecal multitarget DNA test. Gastroenterology. Aug. 2005;129(2):757-59. [pmid: 16083732]. Study design.