# Search Strategy

Database:

Ovid MEDLINE(R) without Revisions <1996 to August 11, 2011>

1. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab.
2. (((fecal or faecal or stool) adj5 (genetic$ or genomic$)) and screen$).ti,ab.
3. ((fecal or faecal or stool) adj5 molecular).ti,ab.
4. (f-dna or fdna).ti,ab.
5. (sdna or s-dna).ti,ab.
6. colosure$.ti,ab.
7. cologuard$.ti,ab.
8. DNA
9. DNA Methylation
10. DNA Mutational Analysis
11. DNA, Neoplasm
12. 8 or 9 or 10 or 11
13. Feces
14. 12 and 13
15. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 14
16. Colorectal Neoplasms
17. Colonic Polyps
18. Colonic Neoplasms
19. Sigmoid Neoplasms
20. Rectal Neoplasms
21. Anus Neoplasms
22. Anal Gland Neoplasms
23. Intestinal Polyps
24. (Colon$ adj5 cancer$).ti,ab.
25. (Colorectal adj5 cancer$).ti,ab.
26. (Colon$ adj5 neoplas$).ti,ab.
27. (Colorectal adj5 neoplas$).ti,ab.
28. or 16-27
29. 15 and 28
30. limit 29 to humans
31. limit 29 to animals
32. 31 not 30
33. 29 not 32
34. limit 33 to english language
35. limit 34 to yr=“2000 -Current”