# Appendixes

Appendix A Search Strategy

Appendix B List of Excluded Studies