# Acknowledgments

The authors gratefully acknowledge the technical expert panel members, peer reviewers, Robert Kane, M.D., Associate Editor, and the following individuals for their contributions to this project: Carrie Patnode, Ph.D., M.P.H., Daphne Plaut, M.L.S., and Kevin Lutz, M.F.A.