# Abbreviations

95% CI: 95 percent confidence interval
ACR: American College of Radiology
ACS: American Cancer Society
AHRQ: Agency for Healthcare Research and Quality
CISNET: Cancer Intervention and Surveillance Modeling Network
CLIA: Clinical Laboratory Improvement Amendments
CMS: Centers for Medicare & Medicaid Services
CRC: Colorectal cancer
CT colonography: Computed tomographic colonography
DCBE: Double contrast barium enema
DIA: DNA integrity assay
DNA: Deoxyribonucleic acid
EHC Program: Effective Health Care Program
ELISA: Enzyme-linked immunosorbent assay
EPC: Evidence-based Practice Center
FAP: Familial adenomatous polyposis
FDA: U.S. Food and Drug Administration
FIT: Fecal immunochemical test
FOBT: Fecal occult blood test (usually used to refer to guaiac based tests like Hemoccult II™ or Hemoccult SENSA™ versus immunochemical based tests for hemoglobin)
FPC: Familial polyposis coli
HNPCC: Hereditary nonpolyposis colorectal cancer
KQ: Key question
LDT: Laboratory-developed test
MBD: Methyl-binding domain
miRNA: MicroRNA
mRNA: Messenger RNA
MSTF: Multi-Society Task Force
NCI: National Cancer Institute
NPV: Negative predictive value
NR: Not reported
PCR: Polymerase chain reaction
PPV: Positive predictive value
RNA: Ribonucleic acid
sDNA: Stool DNA test
SES: Socioeconomic status
SIP: Scientific Information Packet
TEP: Technical Expert Panel
USPSTF: U.S. Preventive Services Task Force
WHO: World Health Organization