# Technical Expert Panel

Joseph Betz, Ph.D.

Director, Office of Dietary Supplements

National Institutes of Health

Bethesda, MD

Ryan Bradley, N.D., M.P.H.

Affiliate Clinical Researcher

Division of Cardiology

University of Washington Medical School

Seattle, WA

Charles Laporte, Pharm.D., Ph.D.

Associate Scientist

Ottawa Hospital Research Institute

Ottawa, ON

Alice Lichtenstein, D.Sc.

Professor of Nutrition Science and Policy

Tufts University

Boston, MA

Edgar (Pete) Miller, M.D., Ph.D.

Associate Professor

Department of Medicine

Johns Hopkins Medical University

Baltimore, MD

Gail Moreschi, M.D., M.P.H., F.A.C.P.

Medical Officer

Center for Drug Evaluation and Research

Food and Drug Administration

Rockville, MD

Norman Stockbridge, Ph.D.

Center for Drug Evaluation and Research

Food and Drug Administration

Silver Spring, MD

Wendy Weber, N.D., Ph.D., M.P.H.

Program Officer

Division of Extramural Research

National Center for Complementary and Alternative Medicine

National Institutes of Health

Bethesda, MD