# Results

## Screening and Inclusion of Records

Overall, 33,224 records were identified by searches of databases after removing all duplicates. The PRISMA diagram in Figure 2 depicts the flow of retrieved records through the phases of screening and inclusion.

Figure 2 PRISMA flow chart of study identification, screening, eligibility, and inclusion

Figure 2. PRISMA flow chart of study identification, screening, eligibility and inclusion. This is a flow chart that summarizes the number of citations identified, screened, excluded, and included. A total of 33 224 citations were screened by title. Of these, 12 178 citations passed on to title and abstract screening. At the full-text level, 2048 articles were assessed; 1980 were English records and 68 were German records. Of these, 1 797 articles were excluded for the following reasons: no dietary supplement or no relevant dietary supplement (n=910), population was not relevant (n=563), study design was not relevant (n=302), and record was not of English or German language (n=22). One-hundred sixty nine articles, all of English language, passed through. However, only 80 articles comprising 70 unique primary studies were included in the evidence synthesis. Articles were excluded from evidence synthesis for the following reasons: cardiovascular drug was taken by less than 80% of the population (n=72), there was no outcome of interest (n=6), a systematic review that was not current (n=1), cardiovascular drug not marketed in the United States (n=4), dose of supplement not stated (n=1), data could not be obtained (n=1), higher level randomized-controlled trial evidence was available (n=1), and other (n=2). The number of studies included in quantitative analyses (i.e. meta-analyses) was 21.

A total of 169 English publication studies were included after title/abstract, and full text screening. None of the 68 German publications screened at full text level met the eligibility criteria. Eighty-nine studies were subsequently excluded from the data synthesis for the following reasons:

- Proportion of population taking cardiovascular drugs was less than 80 percent, preventing accurate analysis of interaction of supplement and cardiovascular drug (n=72);
- No outcome of interest was reported (n=6)135–140
- Cardiovascular drug was not used in U.S.A. (n=4)141–144
- Dose of supplement was not reported (n=1)145
- Outcome data were reported only for the first period crossover (n=1)146
- A sequential study was not included in synthesis of evidence because higher quality randomized controlled trial (RCT) evidence was available for the same pharmacokinetic outcome, for the same drug-supplement combination (n=1)147
- No response was received to a data request made to authors (n=1)148
- High quality systematic review was of limited utility because it was out of date. Inclusion would have necessitated a de novo process for the included studies; (n=1)149 (In two separate records).
- Observational study reported outcomes where higher level of evidence was available from RCT for the same outcomes (n=1)150

As a result, 80 reports were included in the evidence synthesis of this review and entered the quality assessment and data extraction. Among these, seven studies were reported in more than one publication, amounting to 18 records (Table 9). We identified one of these records as the primary report of the study and other(s) as a companion; however, relevant data from all related reports were used in the evidence syntheses. With this approach, 70 primary studies were included and are referenced accordingly in this review (Table 9). One of the included studies was observational,88 two were controlled clinical trials,62,79 and the remaining 66 studies were RCTs.

Table 9 Primary and companion records for studies with multiple reports

Primary Record | Companion Record(s)
Budoff 2004^63^ | Budoff 2006^153^
Chan 2002^44^ | Chan 2006, Chan 2003, Chan 2002, Chan 2010, Chan 2002, Chan 2002^138,154–158^
Davidson 2007^40^ | Maki 2010^159^
Gardner 2007^66^ | Chan 2002^157^
Nordøy 1998^160^ | Nordøy 2000^76^
Nordøy 2003^92^ | Nordøy 2001^161^
Roth 2009^56^ | Bays 2009^162^

Twenty two RCT studies contributed to meta-analyses and the remaining were included in the qualitative syntheses of evidence.36,37,40,44,53,67,68,73,74,76,77,83–86,91,93–96,151,152

We contacted authors of two records requesting additional data or seeking data clarification.39,148 One of the authors,39 responded to our query and provided additional data which was incorporated in the evidence syntheses.

Comprehensive individual study data and quality assessment are presented in Appendix C.

## Key Question 1 In adults taking cardiovascular drugs, what are the effects of concomitant use of specific dietary supplements (when compared to cardiovascular drugs alone or cardiovascular drugs and a different dietary supplement[s]) on clinical cardiovascular effectiveness/efficacy outcomes (e.g., mortality and specific cardiovascular or cerebrovascular conditions such as myocardial infarction [MI] and stroke)?

a. Do the effect estimates of clinical cardiovascular outcomes vary by age, ethnicity, gender, or health status?
b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for clinical cardiovascular outcomes?

### Overview

Twenty-one RCTs addressed Key Question 1.^36–56^ No relevant data were available from observational studies. No evidence on clinical outcomes was found for Echinacea, garlic, ginger, ginseng, hawthorn, niacin (not more than 250 mg/day), red yeast rice extract, resveratrol, vitamin A, and vitamin D with or without calcium supplementation (Table 10). There was insufficient evidence for the gradable outcomes of hospitalization and those related to peripheral arterial disease across all supplement-cardiovascular drug(s) combinations, due to lack of data. A paucity of studies for each supplement-drug combination of interest precluded exploration of heterogeneity in terms of pre-identified subgroups (Key Question 1a). No study examined any statistical interaction between supplement and drug on clinical outcomes (Key Question1b). Table 11 summarizes characteristics of included studies and Table 12 summarizes their risks of bias. Below we report results separately for each supplement and cardiovascular drug combination, by outcomes for which evidence was available. We then grade the evidence for the prestated gradable outcomes, and summarize the PICOTS determinants of applicability for conclusive results across all outcomes—that is, when results were not impacted by the possibility of type II error. In all analyses, the intervention was administration of a dietary supplement along with one or more cardiovascular drug or class of drugs, while the comparator was administration of the drug or its class alone. Details of individual study characteristics, risk of bias and outcomes data are reported in Appendix C.

Table 10 Overview of availability of evidence for clinical outcomes—Key Question 1

Supplement and Cardiovascular Drug(s) | Outcome | Number of Studies
Coenzyme Q10
Statins (Dm) | Adherence | 1
ACE inhibitor with other CV drugs (Dm) | Mortality | 1^*^
ACE inhibitor with other CV drugs (Cs) | Quality of life | 1^*^
Ginkgo biloba
Aspirin (Dm) | Mortality | 1
Aspirin (Cs) | Other clinical outcomes | 1 (NRS)
Magnesium (oral)
Beta-blocker (Dm) | Myocardial infarction | 1^*^
Omega-3 fatty acids/fish oils
Statins (Dm) | Adherence | 3^*^
| Mortality | 1^*^
| Arrhythmia | 1
| Other clinical outcomes | 1 (exacerbation of CHF)
Calcium channel antagonist plus aspirin (Dm) | Myocardial infarction | 1
| Procedures | 1 (CABG and PCI)
| Other clinical outcomes | 1 (Restenosis)
Aspirin plus dipyridamole plus calcium channel antagonist (Dm) | Other clinical outcomes | 1 (Restenosis)
Aspirin plus dipyridamole plus calcium channel antagonist (Cs) | Other clinical outcomes | 1 (Restenosis)
Aspirin (Dm) | Other clinical outcomes | 1 (Graft occlusion^†^)
Warfarin (Dm) | Other clinical outcomes | 1 (Graft occlusion)
Calcium channel antagonist (Cs) | Other clinical outcomes | 1 (induced coronary vasospasm)
Fibrates (Dm) | Mortality | 1
Vitamin E
Aspirin (Dm) | Composite outcome | 1
| Stroke | 1
| TIA | 1
Statin (Dm) | Adherence | 1
Calcium channel antagonist (Cs) | Unstable angina | 2
Vitamin K
W (Dm) | Adherence | 1
| Mortality | 1
| Stroke | 1

Notes:

* At least one crossover RCT;

† omega-3 fatty acids supplement also contained α-tocopherol

Abbreviations: ACE = angiotensin converting enzyme; CABG = coronary artery bypass grafting; CHF = congestive heart failure; Cs = outcomes data were continuous; Dm = outcomes data were dichotomous; NRS = neurologic recovery score; PCI = percutaneous coronary intervention; QoL = quality of life; RCT = randomized controlled trial; TIA = transient ischemic attack; UA = unstable angina.

Table 11 Summary of study characteristics for studies addressing clinical outcomes

Study Characteristic | Distribution
Sample CHD risk | Low 4.8% Moderate to moderately high 4.8% High 43% Mixed 14% Unclear 33%
Geographical region | North America 33% Europe 24% Australia/New Zealand 10% East Asia 14% Rest of Asia 10% NR 9%
Setting | Primary care/community 38% Specialty care 24% NR 38%
Duration | Mean 41 weeks (SD 112), range 2 weeks to 10 years
Total N randomized | Mean 1043(SD 4330), range 11 to 19,934, total across studies = 21895
Age | Mean age 56 years (SD 9)
Gender | Two trials exclusively in males,44,52 and one in females.39 Of the mixed gender studies, 60% included females representing less than 40% of study sample.
Race/Ethnicity | Eight studies reported race/ethnicity distribution. Most included a majority of Caucasian participants. One study included all Asians and another majority Hispanics.50,55

Abbreviations: CHD = cardiovascular heart disease; SD = standard deviation.

Table 12 Risk of bias and potential for conflict of interest for studies addressing clinical outcomes

Items | % of Total RCTs
All RCTs (N=21) | Yes | No | Unclear
Adequate generation of allocation sequence | 38 | 0 | 62
Allocation concealment | 5 | 0 | 95
Comparability of groups | 19 | 19 | 62
Purity of supplement | 71 | 19 | 10
Blinding of allocated intervention | 43 | 5 | 52
Adequately addressed missing data | 52 | 0 | 48
Freedom from potential conflict of interest | 24 | 33 | 43
Crossover RCTs (N=4)
Suitability of crossover design for the study condition | 100 | 0 | 0
Freedom from carryover effect | 50 | 25 | 25
Appropriateness of statistical analysis for crossover design | 0 | 50 | 50
Comparability of groups between periods 1 and 2 | 25 | 0 | 75
Freedom from bias introduced by dropouts | 100 | 0 | 0

Abbreviations: N = total number; RCTs = randomized controlled trials.

### Coenzyme Q10

#### Coenzyme Q10 Plus ACE Inhibitors Versus ACE Inhibitors Alone

All-cause mortality and quality of life. These outcomes were reported in one crossover randomized placebo-controlled trial with a duration of 3 months, in 30, mostly male patients with left ventricular dysfunction, at a specialty center. Coenzyme Q10 (33 mg three times daily) plus maximally tolerated doses of angiotensin-converting enzyme (ACE) inhibitors was compared with ACE inhibitors alone. The majority of patients (i.e., greater than 80 percent) were also taking digoxin, furosemide, hydralazine and/or nitrates. A single death in the placebo group was noted.54 No significant differences were noted in quality of life scores using the Minnesota “Living with Heart Failure” questionnaire (mean sum of all scores posttreatment 26.7±17.9 versus 26.5±18.7). It is not clear whether the statistical analysis incorporated within patient differences in order to fully utilize the robustness of this crossover design. The strength of evidence is summarized in Table 13.

Table 13 Strength of evidence for ACE inhibitors with or without coenzyme Q10—Clinical outcomes

Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
All-cause mortality
Moderate | NA | Direct | Imprecise | Insufficient | The study was grossly underpowered for this outcome
Quality of life
Moderate | NA | Direct | Imprecise | Insufficient | No significant differences were noted. Type II error could not be excluded.

Abbreviations: ACE = angiotensin converting enzyme; NA = not applicable.

#### Coenzyme Q10 Plus Statins Versus Statins Alone

Adherence. A 12-week pilot study of limited internal validity (unclear adequacy of sequence generation, allocation concealment and blinding) assessed adherence to statins. A select group of patients with moderate to high 10 year coronary heart disease (CHD) risk and self reported statin associated myalgia were included. The trial did not demonstrate any difference in rates of adherence to simvastatin (10 mg/day to 40 mg/day) between add-on coenzyme Q10 (200 mg/day) and statin alone in patients with previous statin related myalgia. Adherence to simvastatin was 98 percent in both groups, but it is not clear how adherence was assessed.38

### Ginkgo Biloba

#### Ginkgo Biloba Plus Antiplatelets Versus Antiplatelets Alone

All-cause mortality and neurologic recovery score. These outcomes with G.biloba extract (40 mg every six hours) were investigated over 4 weeks in 62 South Asian patients with previous ischemic stroke, who were on regular aspirin and/or pentoxphilline.48 Trial limitations included unclear allocation concealment, attrition bias, and potential imbalance between groups in terms of the nature of neurologic deficits. The trial was clearly underpowered and of too short duration to detect differences in all-cause mortality and neurologic improvement in the modified Mathew’s scale. There were no deaths and no significant differences in neurologic recovery score after one month of treatment. The mean relative change from baseline in linear transformed Mathew’s scale averaged approximately 20 in both groups, and showed improvement over time (mean difference (MD)) 0.81 [95 percent confidence interval (CI) −9.12, 10.74]).48 Strength of evidence is summarized in Table 14.

Table 14 Strength of evidence for aspirin and/or pentoxphilline with or without Ginkgo biloba—Clinical outcomes

Outcome | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
All-cause mortality | Moderate | NA | Direct | Imprecise | Insufficient | The study was grossly underpowered for this outcome

Abbreviation: NA = not applicable.

### Oral Magnesium

#### Magnesium Plus Beta-Blockers Versus Beta-Blockers Alone

Myocardial infarction. A single event of myocardial infarction was observed in a randomized crossover controlled trial of oral magnesium aspartate (365 mg daily) or placebo administered daily for 8 weeks to a selected group of 40 hypertensive patients with no comorbidities, on therapeutic doses of beta-blockers. The trial was underpowered to detect differences in clinical outcomes and lacked a clear description of several risk of bias items.42 Strength of evidence is summarized in Table 15.

Table 15 Strength of evidence for beta-blockers with or without magnesium—Clinical outcomes

Outcome | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
Myocardial Infarction | Moderate | NA | Direct | Imprecise | Insufficient | The study was grossly underpowered for this outcome

Abbreviations: NA = not applicable.

### Omega-3 Fatty Acids/Fish Oils

#### Omega-3 Fatty Acids/Fish Oils Plus Statins Versus Statins Alone

Mortality, arrhythmia, and adherence to medication. These outcomes were assessed in five trials.

Zero mortality in one randomized crossover pharmacokinetic study of omega-3 fatty acids (4 g/day) with atorvastatin (80 mg/day) versus atorvastatin monotherapy, over 14 days in 50 healthy nonsmoking adults provided insufficient evidence.36

In another study, a single case of supraventricular tachycardia (in the add-on 4 g/day omega-3 fatty acid group) in an 8-week efficacy trial in 256 highly selected dyslipidemic patients on statin therapy constituted insufficient evidence for the arrhythmia outcome.40 There was also one case of exacerbation of congestive heart failure in the add-on omega-3 fatty acid group.40

Rates of adherence to statin therapy were reported in three efficacy trials of 6 to 12 weeks duration in highly selected patient populations with dyslipidemia with or without add-on 4 to 9 g/day of omega-3 fatty acids. All studies had unclear risk of bias for adequacy of sequence generation and allocation concealment. Adherence to statin therapy was judged by pill count. No differences in statin adherence rates were noted between both groups – across all three studies, adherence rates in the two groups were equal to or greater than 95 percent.37,44,53 Strength of evidence is summarized in Table 16.

Table 16 Strength of evidence for cardiovascular drug(s)^*^ with or without omega-3 fatty acids/fish oils—Clinical outcomes

| Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
Statins
All-cause mortality and arrhythmia | Moderate | NA | Direct | Imprecise | Insufficient | Studies were grossly underpowered for both outcomes
Aspirin, warfarin or fenofibrate
All-cause mortality | Moderate | NA | Direct | Imprecise | Insufficient | Studies were grossly underpowered. Aspirin+omega-3 fatty acids RR 1.29 (95% CI 0.35, 4.72) Warfarin+omega-3 fatty acids RR 1.25 (95% CI 0.21, 7.38) Fenofibrate+omega-3 fatty acids RR was not estimable because of zero deaths
Aspirin and calcium channel antagonist
Acute myocardial infarction | Moderate | NA | Direct | Imprecise | Insufficient | Single study, underpowered for clinical events

* Cardiovascular drugs were aspirin, warfarin, or fenofibrate

Abbreviations: CI = confidence interval; NA = not applicable; RR = relative risk

#### Omega-3 Fatty Acids/Fish Oils Plus Cardiovascular Drugs Versus Cardiovascular Drugs Alone

Mortality, myocardial infarction, cardiovascular procedures, restenosis, coronary vasospasm, and graft occlusion. These outcomes were assessed with various cardiovascular drugs. Insufficient evidence from single efficacy trials with sparse events did not demonstrate a difference in the outcome of all-cause mortality when study cardiovascular drugs were either aspirin (291 high risk patients followed for 1 year, with nine deaths), warfarin (319 high risk patients followed for 1 year with 5 deaths), or fenofibrate (unclear 10 year CHD risk in 167 participants with hypertriglyceridemia followed for 8 weeks with no deaths) (Table 16).47,56

In a 6 month efficacy study of omega-3 fatty acids daily (1.8 g eicosapentaenoic acid plus 1.2 g docosahexaenoic acid) in addition to therapeutic doses of aspirin plus calcium channel antagonist versus the latter two drugs alone, six cases of acute myocardial infarction were identified among 58 patients who had undergone successful coronary angioplasty (relative risk [RR] 1.70 [95 percent CI 0.32, 8.84]) (Table 16).51 The same study reported non-significant differences among 26 patients requiring subsequent angioplasty (RR 1.35 [95 percent CI 0.68, 2.70]) and four who underwent coronary artery bypass graft (RR 0.84 [95 percent CI 0.12, 5.78]).51

Coronary artery restenosis. Rates of restenosis were investigated with coronary angiography three to four months following successful angioplasty, in 82 highly selected male patients. Although it was not an a priori outcome for this review, we are reporting restenosis because of its clinical relevance.52 Restenosis was defined as 50 percent narrowing of the luminal diameter. Outcome assessors were blinded to treatment allocation. In this randomized trial, patients were treated either with a daily dose of 3.2 grams of eicosapentaenoic acid added to therapeutic doses of the combination of aspirin, dipyridamole, and calcium channel antagonists, or the latter three drugs in combination. Significantly lower rates of restenosis were observed in the treatment group (RR 0.40 [95 percent CI 0.20, 0.82]); however, the mean percentage reduction in luminal diameter was not significantly different between the two groups. These results conflict with a similar trial conducted in India in 107 patients, that found no significant difference in rates of early restenosis (RR 1.33 [95 percent CI, 0.76, 2.30]).51 Restenosis rates were not significantly influenced by gender or age (p greater than 0.05 for interaction).51 Possible explanations for these differing trial results, besides differences in patient populations, include that in the Indian trial patients were not treated with dipyridamole, and in the same trial followup angiography was only conducted in those with angina symptoms or a positive exercise test (unlike the previously discussed trial that undertook followup angiography in all patients), thereby potentially biasing the results by excluding healthier individuals.

Coronary vasospasm induced by intracoronary acetylcholine was studied in 22 Japanese patients with variant angina randomized to 4 months treatment with therapeutic doses of diltiazem plus eicosapentaenoic acid (1.8 g/day), or diltiazem alone. Patients served as their own controls. Acetylcholine induced vasoconstriction, measured as percentage change in post nitrate coronary artery diameter compared to the baseline response, was significantly improved in those receivingomega-3 fatty acids but not in the control group.50 The report was unclear as to how the randomization sequence was generated, allocation was concealed, and outcome assessors were blinded. Based on the reported data, our comparative analysis of posttreatment percentage change in coronary artery diameter following intracoronary acetylcholine injection showed nonsignificant differences between supplement plus diltiazem and diltiazem alone groups (percentage mean difference in spastic segment was −1.3 [95 percent CI −10.34, 7.74)] and in nonspastic segments was 0.9 [95 percent CI −4.56, 6.36])

Coronary bypass graft occlusion rates were evaluated after one year, in 610 participants on either aspirin (300 mg/day) or warfarin (target prothrombin International Normalized Ratio [INR] 2.5–4.2), in conjunction with placebo oromega-3 fatty acids (4 g/day) plus α-tocopherol (15 mg/day) as an anti-oxidant.47 Graft occlusion was predefined as visualization of the lack of contrast flow on followup angiography. An important limitation of this randomized trial was its lack of clear reporting of adequate allocation concealment. No significant differences in graft occlusion rates were noted, but studies were underpowered to detect a difference (Table 17).

Table 17 Graft occlusion rates with omega-3 fatty acids/fish oils and α-tocopherol—Clinical outcomes

Occlusion Subtype | Drugs and Supplements | RR (95% CI)
Internal mammary artery graft occlusion
| Warfarin+ omega-3 fatty acids+ α-tocopherol | 1.25 (0.70, 2.23)
| Aspirin+ omega-3 fatty acids+ α-tocopherol | 1.03 (0.50, 2.14)
Vein graft occlusion, distal anastomosis
| Warfarin+ omega-3 fatty acids+ α-tocopherol | 0.84 (0.66, 1.07)
| Aspirin+ omega-3 fatty acids+ α-tocopherol | 0.83 (0.65, 1.06)
Patients with > 1 occluded vein graft
| Warfarin+ omega-3 fatty acids+ α-tocopherol | 0.79 (0.62, 1.01)
| Aspirin+ omega-3 fatty acids+ α-tocopherol | 0.89 (0.69, 1.15)

Abbreviations: CI = confidence interval; RR = relative risk.

### Vitamin E (α-Tocopherol)

#### Vitamin E Plus Cardiovascular Drug Versus Cardiovascular Drug Alone

Stroke, transient ischemic attacks, adherence, angina, myocardial infarction, and vascular death. These outcomes were assessed in five trials.

In an efficacy trial, 100 highly selected patients with previous reversible or irreversible ischemic neurologic deficit and good performance status presenting to a university hospital were randomized to vitamin E (0.4 g/day) plus aspirin (325 mg/day) versus aspirin alone for a period of two years. Nine patients experienced outcomes of stroke (seven ischemic, two hemorrhagic), and three experienced recurrent transient ischemic attack, precluding definitive conclusions (Table 18).49

Table 18 Strength of evidence for aspirin with or without vitamin E—Clinical outcomes

| Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
Aspirin
All stroke, ischemic stroke, hemorrhagic stroke and transient ischemic attacks | Moderate | NA | Direct | Imprecise | Insufficient | Small efficacy trial clearly underpowered for clinical events

Abbreviation: NA = not applicable

Adherence to a statin was reported in one trial that randomized a highly selected group of 220 hypercholestrolemic patients with normal triglycerides on a standardized diet of 100 mg/day of vitamin E plus 20 to 40 mg/day of pravastatin versus pravastatin alone.46 Ninety-eight percent of all patients were compliant with their treatment.

In one pragmatic trial in 19,934 women randomized to vitamin E (600 IU/day) plus aspirin (100 mg/day) versus aspirin alone for 10 years, no significant differences were noted for the composite outcome of nonfatal myocardial infarction, nonfatal stroke, and vascular death (RR 0.95 [95 percent CI 0.79, 1.13]).39 Data regarding the total number of participants randomized into the two groups were obtained from the authors. Although components of the composite outcome were gradable, it was not possible to discern if shifts in incidence of stroke and heart attack might have been obscured in this composite outcome.

Two trials, each of one month duration, in a total of 60 highly selected Japanese patients with variant angina, were inconclusive for the mean number of angina attacks per patient following addition of vitamin E (400 mg/day) to therapeutic doses of diltiazem (MD −0.40 [95 percent CI −0.88, 0.08]) (Figure 3).43,45

Figure 3 Forest plot of the mean number of angina attacks for participants administered aspirin with or without vitamin E

Figure 3 is a forest plot that displays effect estimates for mean number of angina attacks in participants administered aspirin plus vitamin E versus aspirin alone. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −0.40, lower bound 95% confidence interval −0.88, upper bound 95% confidence interval 0.08). Heterogeneity was present (I2 = 80.13%, chi-squared = 5.03, p-value = 0.02).

### Vitamin K

#### Vitamin K Plus Warfarin Versus Warfarin Alone

Mortality, stroke, and adherence to cardiovascular medication. Insufficient evidence was found for mortality and stroke. One 6 month efficacy trial in 70 selected patients with unstable INRs, anticoagulated with warfarin, reported no stroke and one death.41 During the 6 month study period, two of 35 patients failed to take their warfarin and the supplement on a single occasion.41 Strength of evidence is summarized in Table 19.

Table 19 Strength of evidence for warfarin with or without vitamin K—Clinical outcomes

Cardiovascular drug/Outcome | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence | Conclusions
All-cause mortality and stroke | Moderate | NA | Direct | Imprecise | Insufficient | Two small trials clearly underpowered for clinical events

Abbreviation: NA = not applicable

### Key Question 1a Do the effect estimates of clinical cardiovascular outcomes vary by age, ethnicity, gender, or health status?

A paucity of studies of supplement-drug combinations for which data were available precluded exploration of heterogeneity in terms of pre-identified subgroups.

### Key Question 1b Is there a measurable interaction between cardiovascular drugs and dietary supplements for clinical cardiovascular outcomes?

No study analyzed statistical interaction between a supplement and a cardiovascular drug on clinical outcomes.

### Main Points for Key Question 1: Clinical Outcomes

For Key Question 1, we compared dietary supplement(s) coadministered with cardiovascular drug(s), with the cardiovascular drug(s) alone, to investigate comparative clinical efficacy/effectiveness, subgroup effects and statistical interactions.

- Twenty-one randomized controlled trials contributed evidence.
- For all predetermined gradable clinical outcomes for which evidence was found, the strength of evidence of comparative efficacy or effectiveness was graded insufficient because type II error could not be excluded due to the low power of studies. When compared with the specific cardiovascular drug alone, insufficient evidence was found for an effect of coenzyme Q10 coadministered with ACE inhibitors on all-cause mortality and quality of life; Ginkgo biloba plus aspirin and/or pentoxyphilline on all-cause mortality; oral magnesium and beta-blockers on myocardial infarction; omega-3 fatty acids plus statins on all-cause mortality and arrhythmia; omega-3 fatty acids plus aspirin, warfarin or fenofibrate on all-cause mortality; omega-3 fatty acids plus aspirin and calcium channel antagonist on acute myocardial infarction; vitamin E plus aspirin on stroke and transient ischemic attacks; and vitamin K plus warfarin derivative on all-cause mortality and stroke.
- No differences in adherence to statins were noted with coadministration of coenzyme Q10, omega-3 fatty acids, and vitamin E, with adherence rates greater than 90 percent in both drug plus supplement and drug alone groups. Evidence supporting benefit of omega-3 fatty acids added to conventional antiplatelet therapy and calcium channel antagonists on rates of restenosis following successful coronary angioplasty is conflicting. Underpowered studies addressed all other outcomes such as exacerbation of congestive heart failure, number of patients undergoing cardiac procedures, graft occlusion, neurologic recovery score, coronary vasospasm, and number of angina attacks in patients with variant angina for various dietary supplement and cardiovascular drug combinations
- Most studies were short-term efficacy trials, except for one pragmatic trial on 19,934 women randomized to vitamin E (600 IU/day) plus aspirin (100 mg/day) versus aspirin alone for 10 years. In this trial, no significant difference was noted for the composite outcome of nonfatal myocardial infarction, nonfatal stroke, and vascular death (RR 0.95, 95 percent CI, 0.79, 1.13).
- With no data, there was insufficient evidence for the outcomes of hospitalization and those related to peripheral arterial disease across all supplement-cardiovascular drug(s) combinations.
- No evidence on clinical outcomes was found for Echinacea, garlic, ginger, ginseng, hawthorn, niacin (not more than 250 mg/day), red yeast rice extract, resveratrol, vitamin A, and vitamin D (with or without calcium supplementation) coadministered with a cardiovascular drug(s)
- A paucity of studies of supplement-drug combinations for which data were available precluded exploration of heterogeneity in terms of pre-identified subgroups, or documentation of any dose-response effect.
- No study analyzed statistical interaction between a supplement and a cardiovascular drug on clinical outcomes.

## Key Question 2 In adults taking cardiovascular drugs, what are the effects of concomitant use of specific dietary supplements (when compared to cardiovascular drugs alone or cardiovascular drugs and a different dietary supplement[s]) on intermediate cardiovascular efficacy outcomes (e.g., lipids, blood pressure, electrocardiographic measurements, serum markers, bleeding, and coagulation times)?

a. Do the effect estimates of intermediate cardiovascular outcomes vary by age, ethnicity, gender, or health status?
b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for intermediate cardiovascular outcomes?

### Overview

Fifty-eight RCTs and one controlled clinical trial addressed Key Question 2. The availability of evidence is summarized in Table 20. The dietary supplements used in the studies were the following: coenzyme Q10 (five studies),38,54,57,58,89 Echinacea (one study),59 garlic (four studies),60–63 ginger (one study),64 Ginkgo biloba (five studies),64–68 ginseng (three studies),69–71 hawthorn (one study),72 magnesium (three studies),42,73,74 niacin (one study),75 omega-3 fatty acids (24 studies),37,40,44,50–53,55,56,76–78,91,92,94–99,151,152,163,164 vitamin E (11 studies),46,49,79–87 and vitamin K (one study)41. No evidence was identified for effects of red yeast rice extract, resveratrol, vitamin A, or vitamin D in combination with cardiovascular drugs on intermediate outcomes. No study addressed the following outcomes: incidence of metabolic syndrome; incidence of hypotension; carotid-intima media thickness; or change in 10-year Framingham risk profile. Two studies examined statistical interaction.44,78 One study used general linear modeling to assess interaction between fish/marine oils and atorvastatin on lipid parameters.44 The other study used ANOVA to assess interaction between omega-3 fatty acids and niacin plus aspirin on triglyceride levels.78 No relevant data were available from observational studies. One systematic review reporting the effectiveness of concomitant administration of omega-3 fatty acids plus statins compared with statins alone on lipid profiles in participants requiring lipid lowering therapy149 was not included for synthesis because it was determined to be out of date. Details of individual study characteristics, risk of bias and outcomes data are reported in Appendix C.

Table 20 Overview of availability of evidence for intermediate outcomes—Key Question 2

Supplement and Cardiovascular Drug(s) | Outcome | Number of Studies
Coenzyme Q10
ACE inhibitors^*^ | Ejection Fraction | 1
Fenofibrate | Lipid Profile Blood Pressure – Systolic | 1
Statins | Lipid Profile | 3
Echinacea
Warfarin | INR Platelet Aggregation | 1
Garlic
Nitrates | Lipid Profile | 1
Statins + Aspirin | Lipid Profile CRP Platelet Count Coronary Artery Calcification | 1
Warfarin | Lipid Profile Blood Pressure – Systolic and Diastolic Platelet Count Platelet Aggregation | 1
| INR | 2
Ginger
Warfarin | INR Platelet Aggregation | 1
Ginkgo biloba
Aspirin | Lipid Profile Blood Pressure – Systolic and Diastolic Clotting Time Platelet Count Partial Thromboplastin Time | 1
| Platelet Aggregation | 2
Antiplatelet drugs – thienopyridines | Blood Pressure – Systolic Clotting Time Platelet Count | 1
| Platelet Aggregation Bleeding Time | 2
Cilostazol | Blood Pressure – Systolic Platelet Aggregation Clotting Time Platelet Count | 1
Warfarin | INR Platelet Aggregation | 1
Ginseng
Warfarin | INR | 3
| Prothrombin Time Platelet Count Platelet Aggregation | 1
Hawthorn
Digoxin | PR Interval | 1
Magnesium
Beta-Adrenergic Antagonists | Blood Pressure – Systolic and Diastolic | 1
Hydrochlorothiazide | Lipid Profile | 1
| Blood Pressure – Systolic and Diastolic | 2
Niacin ≤ 250 mg
Propranolol | Lipid Profile | 1
Omega-3 fatty acids/fish oils
ACE inhibitors | Lipid Profile Blood Pressure – Systolic and Diastolic | 2
| Urinary Protein Excretion Reduction in Proteinuria | 1
Aspirin | Lipid Profile Platelet Count | 2
| Blood Pressure – Systolic and Diastolic | 1
Beta-Adrenergic Antagonists | Blood Pressure – Systolic and Diastolic | 1
Calcium Channel Blockers | Lipid Profile | 1
Calcium Channel Blockers with + Aspirin (with or without dipyridamole) | Lipid Profile | 2
| Platelet Count | 1
Fenofibrate | Lipid Profile Incidence of Hypertension | 1
Niacin + Aspirin | Lipid Profile | 1
Statins | Lipid Profile | 11
| Blood Pressure – Systolic and Diastolic Platelet Count | 3
| CRP Blood Coagulation | 1
Warfarin | INR | 1
Vitamin E
Antiplatelets | Lipid Profile Platelet Aggregation | 1
Furosemide | Blood Pressure – Systolic and Diastolic | 1
Gemfibrozil | Lipid Profile Blood Pressure – Systolic and Diastolic | 1
Nifedipine | Lipid Profile Blood Pressure – Systolic and Diastolic | 1
Statins | Lipid Profile | 6
| CRP Prothrombin Time Platelet Count | 1
Vitamin K
Anticoagulants | INR | 2

Note:

* Subjects were also taking digoxin, furosemide, hydralazine, or nitrates.

Abbreviations: ACE = angiotensin converting enzyme; CRP = C-reactive protein; INR = international normalized ratio

Participant and study characteristics are summarized in Table 21.

Table 21 Summary of study characteristics for studies addressing intermediate outcomes—Key Question 2

Characteristic | Distribution
Sample CHD risk | - Low 8.0%; - Moderate to moderately high 2.3%; - High 20.3%; - Mixed 33.2%; - Unclear 36.2%
Geographical region | - North America 15.3%; - Europe 28.8%; - Australia/New Zealand 10.2%; - East Asia 6.8%; - Rest of Asia 3.4%; - NR 10.2%
Setting | - Primary care/community 34.0%; - Specialty care 21.7%; - NR 44.3%
Duration | Mean 10 weeks (SD 14.7) Range 1 week to 2 years
Total N randomized | Mean 50.6(SD 51.7), range 10 to 332, total across studies = 3,201
Age | Mean age 48.8 years (SD 14.4)
Gender | Ten all-male trials.44,52,59,61,64,65,67,68,71,98 In 28.0% of the mixed gender studies, females were less than 40% of the study sample
Race/Ethnicity | Eighteen (31.0%) studies reported race/ethnicity distribution. Five studies included a majority of Caucasian participants. Three studies included all Asians50,57,68 Two studies included majority of Hispanics55,95

Abbreviations: CHD = coronary heart disease; N = total number in trial; NR = not reported; SD = standard deviation.

Assessment of risks of bias is summarized in Table 22. Among all RCTs the purity of supplement was the item most frequently reported, while underreporting of generation and concealment of allocation represented the greatest potential for bias. In all crossover trials the study design was deemed to be suitable for the studied condition and a majority were judged to be free of carryover effect.

Table 22 Risk of bias and potential for conflict of interest—Key Question 2

Items | Yes | No | Unclear
All RCTs | % of total studies (N=58)
Adequate generation of allocation sequence | 20 | 2 | 78
Allocation concealment | 9 | 0 | 91
Comparability of groups | 9 | 46 | 46
Purity of supplement | 81 | 12 | 7
Blinding of allocated intervention | 22 | 24 | 53
Adequately addressed missing data | 63 | 3 | 34
Freedom from potential for conflict of interest | 24 | 31 | 47
Crossover RCTs | % of total crossover studies (N=19)
Suitability of crossover design for the study condition | 100 | 0 | 0
Free of carryover effect | 26.3 | 63.2 | 10.5
Appropriateness of statistical analysis for crossover design | 21.1 | 21.1 | 57.9
Comparability of groups between periods 1 and 2 | 10.5 | 0.0 | 89.5
Freedom from bias introduced by dropouts | 5.3 | 78.9 | 15.8

Abbreviations: N = total number; RCTs = randomized controlled trials.

### Coenzyme Q10

Five RCTs, including four parallel-arm trials,38,57,58,89 and one crossover trial54 examined cardiovascular drugs with and without coenzyme Q10. The trials were conducted in Australia,38,54,58 North America,89 and East Asia.57 The number of included participants across these trials ranged from 30^54^ to 49,^57^ and they received statins (atorvastatin, simvastatin),38,57 fenofibrate,58 ACE inhibitors (specific agents not stated), or vitamin E89 in addition to other cardiovascular drugs (digoxin, furosemide, hydralazine, nitrates, or statins).54 According to the National Cholesterol Education Program, Adult Treatment Panel III,165 the study participants were categorized as having a high,54,58 unclear,57,89 or mixed (moderate and high)38 risk for CHD. The duration of treatment across the studies ranged from 4 89 to 12 weeks.38,54,57,58 Generally, these studies were reported to be double-blind and had moderate risk of bias across the outcomes of interest. The washout period in the one crossover trial was adequate to minimize or avoid a carryover treatment effect.54 Further details on study, participant, and treatment characteristics are presented in Appendix C.

Summary of findings and strength of evidence data are presented in Table 23. No meta-analysis was possible for coenzyme Q10 studies because when more than one study reported a particular outcome,38,57,89 the treatment effect was either not reported,89 or it was reported as a median (interquartile range) change,38 so the study results were in a format that is unsuitable for statistical pooling.

Table 23 Strength of evidence for cardiovascular drugs with and without coenzyme Q10—Intermediate outcomes

Cardiovascular drug(s)/Outcome | Risk of bias | Consistency | Directness | Precision | Grade | Treatment effect and conclusion^*^ MD (95% CI)
Statins
CRP57 | - | - | - | - | - | No difference 0.02 mg/L (−0.64, 0.68)
HDL-C (mg/dL)38,57 | Moderate | Consistent | Indirect | Imprecise | Insufficient | Inconclusive 5.02 mg/dL (−3.73, 13.77)57 Arm-specific median change 0.39 versus −0.77, p=0.65^38^ †
LDL-C (mg/dL)38,57 | Moderate | Consistent | Indirect | Imprecise | Insufficient | Inconclusive 8.12 mg/dL (−3.79, 20.03) )57 Arm-specific median change −65.73 versus −50.27, p=0.53^38^
TC (mg/dL) 38,57 | - | - | - | - | - | Inconclusive 11.9 (−3.55, 27.53)57 Arm-specific median change −58.00 versus −61.87, p=0.57^38^
TG (mg/dL)38,57 | Moderate | Consistent | Indirect | Imprecise | Insufficient | Inconclusive −21.26 (−48.88, 6.36) 57 Arm-specific median change −35.43 versus −26.57, p=0.90^38^
ACE inhibitors
Ejection fraction (%)54 | - | - | - | - | - | No difference 0 (−4.75, 4.75)
Fenofibrate
HDL-C (mg/dL) 58 | Moderate | NA | Indirect | Precise | Low | No difference −1.55 (−6.78, 3.68)
LDL-C (mg/dL) 58 | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 3.87 (−19.30, 27.04)
TC (mg/dL) 58 | - | - | - | - | - | Inconclusive 0 (−23.17, 23.17)
TG (mg/dL) 58 | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 8.85 (−52.49, 70.19)
Non-HDL-C (mg/dL) 58 | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 0.87 (−22.30, 24.04)
SBP (mmHg) 58 | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive −3.40 (−15.56, 8.76)

Notes:

* Mean difference and 95 percent confidence interval; range for mean difference given only when evidence consists of multiple studies that were not pooled; (−) is indicated where non-gradable outcomes are reported (for example TC, or CRP)

† Arm-specific median change (from baseline) was not used to assess the domain of precision

Abbreviations: ACE = angiotensin-converting enzyme; CHD = coronary heart disease; CRP = C-reactive protein; HDL-C = high density lipoprotein-cholesterol; LDL-C = low density lipoprotein-cholesterol; NA = not applicable; NR = not reported; TC = total cholesterol; TG = triglycerides; RCT = randomized controlled trial; SBP = systolic blood pressure; wk(s) = week(s); yr(s) = year(s).

#### Coenzyme Q10 Plus Statins Versus Statins Alone

C-reactive protein (CRP). One placebo-controlled parallel-arm RCT examined CRP changes in participants with unclear CHD risk.57 The 12-week mean CRP levels were not different between groups with add-on dietary supplement treatment (100 mg/day) versus the statin-only (10 mg/day) group.

High density lipoprotein-cholesterol. Two placebo-controlled parallel-arm randomized trials examined HDL-C changes in participants with unclear or mixed CHD risk.38,57 In one trial, mean HDL-C levels after 12 weeks of treatment were not significantly different for those receiving coenzyme Q10 (100 mg/day) plus statins (10 mg/day) versus those receiving only statins.57 Similarly, in the second trial (200 mg/day coenzyme Q10; 10–40 mg/day statins), there was no significant between-group difference for the median change in HDL-C.38

Low density lipoprotein-cholesterol, total cholesterol and triglycerides. Two trials in participants with mixed38 or unclear CHD risk investigated changes in LDL-C.57 Levels were not significantly different following treatment with coenzyme Q10 plus statins compared with plus statins alone after 12 weeks.38,57 Mean differences 57 and between-group difference for the median change 38 were not significant for LDL-C, total cholesterol, or triglycerides.

#### Coenzyme Q10 Plus Statins Versus Vitamin E Plus Statins

Lipid profile, low density lipoprotein-cholesterol, total cholesterol and triglycerides. In one trial of 32 participants with unclear CHD risk, changes of LDL-C, TC, and TG levels were studied.89 Results from this RCT indicated no differences in lipid profile (total cholesterol, LDL-C, triglycerides) after 30 days of treatment with coenzyme Q10 (100 mg/day) plus statins or vitamin E (400 IU/day) plus statin groups in participants with statin induced myopathic pain (numeric data were not provided).89

#### Coenzyme Q10 Plus ACE Inhibitors Versus ACE Inhibitors Alone

Participants were also taking digoxin, furosemide, hydralazine, and nitrates.

Ejection fraction. One randomized crossover trial reported ejection fraction in participants with heart failure (high CHD risk).54 The 12 week posttreatment ejection fraction in the treatment (coenzyme Q10 [100 mg/day] plus ACE inhibitors) and control (ACE inhibitors alone) groups were not significantly different.

#### Coenzyme Q10 Plus Fenofibrate Versus Fenofibrate Alone

Lipid profiles and systolic blood pressure. One parallel arm randomized trial in participants with type II diabetes and high CHD risk reported changes in systolic blood pressure.58 The 12 week posttreatment mean levels in the treatment (200 mg/day coenzyme Q10 plus 200 mg/day fenofibrate) and control (fenofibrate alone) groups did not significantly differ for any of the outcomes assessed (HDL-C, LDL-C, total cholesterol, triglycerides, non-HDL-C, and systolic blood pressure).

Applicability. Low grade evidence of no effect on HDL-C was found in a primarily (70 percent) male population, of mean age 53 years, with high risk for cardiovascular disease. Treatment was over 12 weeks, with fenofibrate and with or without coenzyme Q10.

### Echinacea

#### Echinacea Plus Warfarin Versus Warfarin Alone

One crossover RCT in 12 healthy male volunteers examined the effect of two weeks pre-treatment with Echinacea (600 mg of E. angustifolia root plus 675 mg of E. purpurea root daily) and a single dose of warfarin (25 mg) versus warfarin alone.59

There was no effect on blood pressure, maximum International Normalized Ratio (INR_max_), geometric mean ratio [GMR] 1.04 [90 percent CI 0.95, 1.13]), AUC of INR (MD 2.50 [95 percent CI −17.72, 22.72] and GMR 1.09 [95 percent CI 0.91, 1.31]), or measures of platelet aggregation (using three different platelet agonists: adenosine diphosphate, arachidonic acid and collagen; data not shown). Strength of evidence is summarized in Table 24.

Table 24 Strength of evidence for warfarin with and without Echinacea—Intermediate outcomes

Cardiovascular Drug(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Treatment Effect and Conclusion MD (95% CI)
Warfarin
Blood pressure | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference Systolic blood pressure: 2.20 mm Hg (−8.98, 13.38) Diastolic blood pressure: −0.80 mm Hg (−8.21, 6.61)
INR_max_ | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference INR_max_ 0.10 (−0.20, 0.40

Abbreviations: CI = confidence interval; MD = mean difference; mm Hg = millimetres of mercury.

### Garlic

Four RCTs, including three parallel-arm trials,60,62,63 and one crossover trial61 examined cardiovascular drugs with and without garlic. The trials were conducted in Australia,61 North America,60,63 and Europe.62 The number of included participants across these trials ranged from 12^61^ to 60,^62^ and they received statins plus aspirin,63 warfarin,60,61 or nitrates.62 According to the National Cholesterol Education Program, Adult Treatment Panel III,165 the study participants were categorized as having a high,62,63 unclear,60 or low 61 CHD risk. The duration of treatment across the studies ranged from one day61 to 12 months.63 The washout period in the one crossover trial was adequate to minimize or avoid a carryover treatment effect. Further details on study, participant, and treatment characteristics are presented in Appendix C. Strength of evidence is summarized in Table 25

Table 25 Strength of evidence for cardiovascular drugs with and without garlic—Intermediate outcomes

Cardiovascular Drug(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect MD (95% CI)
Warfarin
Blood pressure (mmHg) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference Systolic: 2.20 (−8.98, 13.38) Diastolic: −0.80 (−8.21, 6.61)
LDL-C (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference 4.20 mg/dL (−12.01, 20.41)
HLD-C (mg/dL) | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment 4.50 mg/dL (0.19, 8.81)
Total cholesterol (mg/dL) | - | - | - | - | - | No difference 12.50 (−3.74, 28.74)
Triglycerides (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference 31.90 (−23.66, 87.46)
INR | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference INR: −0.20 (−0.83, 0.43) INR_max_ : −0.10 (95% CI −0.63, 0.43) AUC of INR : 4.30 (−35.90, 44.50) INR > 4 No events in either arm
Nitrates
HDL-C (mg/dL) | High | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment 8.40 (1.91, 14.89)
Total cholesterol (mg/dL) | - | - | - | - | - | In favor of combination treatment −28.20 (−48.30, −8.10)
Triglycerides (mg/dL) | High | NA | Indirect(surrogate) | Imprecise | Insufficient | No difference −10.30 (−27.60, 7.00)
Statins + Aspirin
LDL-C (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference −25.10 (−54.69, 4.49)
HLD-C (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference 4.30 (−7.55, 16.15)
Triglycerides (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | No difference −21.20 (−93.42, 51.02)

Abbreviations: AUC = area under the curve; CI = confidence interval; HDL-C = high density lipoprotein-cholesterol; INR = international normalized ratio; LDL-C = low-density lipoprotein cholesterol; MD = mean difference; NA = not applicable; (−) is indicated where non-gradable outcomes (total cholesterol) are reported

#### Garlic Plus Warfarin Versus Warfarin Alone

Two small RCTs, one parallel-group60 and one crossover61 trial, examined the effect of treating patients on warfarin with garlic extracts. Both studies concluded that supplementation with garlic in patients taking warfarin does not further affect INR, based on various measures including INR,60 or INR_max_, AUC of INR, or the number of participants with an INR greater than 4 (no events in either arm).61

One study60 in 48 participants with prosthetic heart valves, or diagnosed with deep vein thrombosis, valvular heart disease, or atrial fibrillation assessed the effects of aged garlic extract (AGE) (10 mL/day) plus warfarin. No significant effects were seen for total cholesterol, LDL-C, or triglycerides. However, there was a statistically significant increase in HDL-C in the combination group. Neither blood pressure, nor platelet count (data not shown) were significantly affected.

One crossover study61 found no significant effect of pretreatment with garlic (4 g single dose) plus a single dose of warfarin (25 mg) on platelet aggregation (using four different agents: adenoside diphosphate, arachidonic acid, collagen and ristocetin; data not presented). Participants in this trial were 16 healthy male adults of known CYP2C9 and VKORC1 genotype.

All results for major review outcomes, aside from HDL-C, were considered to have insufficient strength of evidence (Table 25). The strength of evidence for HDL-C was initially rated as insufficient by one reviewer because the lower bound confidence interval of 0.19 mg/dL is not clinically meaningful. A second reviewer provided a rating of low because the estimate is statistically significant. Adjudication by a third reviewer led to a final rating of low.

#### Garlic Plus Nitrates Versus Nitrates Alone

One controlled clinical trial62 recruited 60 participants with coronary artery disease to receive either garlic oil (4 g/day) or placebo in addition to their prescribed nitrates (specific drugs and doses were not reported). Compared with placebo, administration of garlic was found to significantly decrease total serum cholesterol, and increase serum HDL-C.62 Serum triglycerides were also reduced but the comparison was not statistically significant. These results were considered to provide insufficient strength of evidence for triglycerides and low strength of evidence for HDL-C in favor of combination treatment (Table 25).

#### Garlic Plus Statins and Aspirin Versus Statins and Aspirin Alone

One small parallel group trial63 randomly allocated 23 participants with, or at high risk for coronary artery disease to receive AGE (4 mL,305 g/L of extracted solids/day) or placebo in addition to their prescribed statins (10–40 mg/day) and aspirin (dose not specified) over a period of one year. Compared with placebo, administration of AGE was not found to have a significant effect on lipid parameters (total cholesterol (TC), TC/HDL-C, HDL-C, LDL-C, triglycerides), CRP, or platelet count.

This study also examined two measures of coronary artery calcification: volume calcium score (using isotropic interpolation method) and Agatston calcium score (multiplying the lesion area by a coefficient based on the peak density within plaque). The first measure was found to be lowered significantly by supplementation with garlic compared with placebo (change in volume calcium score: −83.80 mm^3^ [95 percent CI −164.22, −3.38]; percent change in volume calcium score per year: −14.7 mm^3^ [95 percent CI −28.93, −0.47]). No differences were found in the second measure.

Strength of evidence was insufficient for LDL-C, HDL-C, and triglycerides (Table 25).

Applicability. Garlic in addition to nitrates for 3 months was found to significantly improve total cholesterol and HDL-C compared with nitrates alone, in subjects with healed myocardial infarction with or without angina.62 Garlic in addition to statins plus aspirin for 12 months significantly lowered a measure of coronary artery calcification in subjects with known coronary artery disease.63

### Ginger

One crossover RCT compared a single dose of warfarin following seven days pre-treatment with ginger (3.6 g/day) with warfarin alone in 12 healthy male subjects (Table 26).64 The study also included a warfarin plus G. biloba group (data for the comparison between warfarin plus ginger and warfarin plus Ginkgo is in the G. biloba section).

Table 26 Strength of evidence for warfarin with or without ginger—Intermediate outcomes

Cardiovascular Drug(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
AUC of INR64 | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive MD 1.00 (95% CI −43.68, 45.68) GMR 1.01 (90% CI 0.93, 1.15)

Abbreviations: AUC of INR = area under the curve of the international normalized ratio; CI = confidence interval; GMR = geometric mean ratio; MD = mean difference.

The same study reported AUC of INR for the combination of ginger plus warfarin versus warfarin alone.64 One of the two analyses of the data suggests a possible effect of unknown clinical significance. The mean difference in platelet aggregation was not statistically significant (MD 0.6 [95 percent CI −0.42, 1.62]) but the geometric mean ratio was statistically significant. Given the inconsistency in findings, strength of evidence was graded as insufficient for INR (Table 26).

### Ginkgo Biloba

Five RCTs investigated G. biloba with cardiovascular drugs (Table 27).64–68 Four studies included subjects taking antiplatelet agents (aspirin,65,66 clopidogrel,67 or ticlopidine68). One study included subjects taking an anticoagulant (warfarin64) and one study included subjects taking a vasodilator (cilostazol67).

Table 27 Summary and strength of evidence for cardiovascular drugs with or without G. biloba—Intermediate outcomes

Cardiovascular Drug/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Antiplatelet drugs
Bleeding Time (min)67,68 | Moderate | - | - | - | - | Inconclusive Pooled 0.52 (95% CI −0.34, 1.38)
Blood Pressure – Systolic and Diastolic | Moderate | NA | Indirect (surrogate) | NA | Insufficient | Inconclusive
Lipid Profile (LDL-C, HDL-C, TG)65 | Moderate | NA | Indirect (surrogate) | NA | Insufficient | Inconclusive
Warfarin
AUC of INR (versus warfarin alone) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive MD−3.00 (95% CI −62.00, 56.00) GMR 0.93 (90% CI 0.81, 1.05)
AUC of INR (versus warfarin plus ginger) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive MD −4.00 (95% CI −62.84, 54.84)
Cilostazol
Bleeding Time (min)67 | Moderate | - | - | - | - | Inconclusive MD 1.02 (95% CI 0.10, 1.94)
Blood pressure - Systolic | Moderate | NA | Indirect (surrogate) | NA | Insufficient | Inconclusive

Abbreviations: AUC of INR = area under the curve of the International Normalized Ratio; CI = confidence interval; GMR = geometric mean ratio; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MD = mean difference; NA = not applicable; TG = triglycerides.

#### G. Biloba Plus Antiplatelet Agents Versus Antiplatelet Agents Alone

Aspirin was administered with G. biloba in two studies, of young healthy males (240 mg/day G. biloba)65 or elderly subjects with peripheral arterial disease or risk factors for cardiovascular disease (300 mg/day G. biloba).66 Although platelet aggregation was reported in both studies, meta-analysis could not be performed because different posttreatment effect estimates were reported (mean65 and mean change from baseline66). Both studies reported nonsignificant differences in platelet aggregation. Nonsignificant differences were also reported in clotting time,66 bleeding time,65 partial thromboplastin time,65 and platelet count.65 No changes were found in lipid parameters and blood pressure (reported qualitatively only).65

In two studies, single doses of a thienopyridine antiplatelet drug (clopidogrel67 or ticlopidine68) were administered with or without single doses of G. biloba(80 mg/day). The pooled estimates for platelet aggregation were statistically nonsignificant (Figures 4 and 5), as was the pooled estimate for bleeding time (Figure 6). There were no significant changes in clotting time, systolic blood pressure, or platelet count (reported qualitatively only).67

Figure 4 Forest plot of posttreatment mean difference of platelet aggregation for clopidogrel/ticlopidine with or without G. biloba (induced by 5 μL of 10 μM ADP or 2.5 μL of 10 μM ADP)-(percent)

Figure 4 is a forest plot that displays effect estimates for platelet aggregation in participants administered clopidogrel/ticlopidine with or without Ginkgo biloba. Platelet aggregation was induced by 5 μL of 10 μM adenosine diphosphate or 2.5 μL of 10 μM adenosine diphosphate. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −2.37%, lower bound 95% confidence interval −11.77, upper bound 95% confidence interval 7.03). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.04, p-value = 0.84).

Figure 5 Forest plot of posttreatment mean of platelet aggregation for clopidogrel/ticlopidine with or without G. biloba (induced by 5 μL of 10 μM ADP or 2.5 μL of 5 μM ADP)-(percent)

Figure 5 is a forest plot that displays effect estimates for platelet aggregation in participants administered clopidogrel/ticlopidine with or without Ginkgo biloba. Platelet aggregation was induced by 5 μL of 10 μM adenosine diphosphate or 2.5 μL of 5 μM adenosine diphosphate. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −2.06%, lower bound 95% confidence interval −11.72, upper bound 95% confidence interval 7.60). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.01, p-value = 0.92).

Figure 6 Forest plot of bleeding time for clopidogrel/ticlopidine with or without G. biloba- (minutes)

Figure 6 is a forest plot that displays effect estimates for bleeding time in participants administered clopidogrel/ticlopidine with or without Ginkgo biloba. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = 0.52 minutes, lower bound 95% confidence interval −0.34, upper bound 95% confidence interval 1.38). Heterogeneity was minimal (I2 = 21.8%, chi-squared = 1.28, p-value = 0.26).

Strength of evidence was insufficient for blood pressure and lipid profile (Table 27).

#### G. Biloba Plus Warfarin Versus Warfarin Alone

One crossover RCT examined single dose warfarin (25 mg/day) following either no pretreatment or seven days pretreatment with G. biloba (12 g/day) or ginger (3.6 g/day) in healthy subjects.64 Compared with warfarin alone, there was a statistically significant increase in platelet aggregation (GMR 1.14 [90 percent CI 1.08, 1.20]). However, the difference in AUC of INR was not statistically significant. Compared with warfarin plus ginger, there were no statistically significant differences in platelet aggregation or AUC of INR.

Strength of evidence comparing G. biloba plus warfarin with warfarin alone or warfarin plus ginger was insufficient for INR (Table 27).

#### G. Biloba Plus Cilostazol Versus Cilostazol Alone

One crossover RCT examined single dose cilostazol (100 mg) with or without single dose G. biloba (120 mg) in healthy South Asian males.67 Bleeding time was slightly prolonged in the G. biloba plus cilostazol group. One measure of platelet aggregation was statistically significant (MD 18.00 percent [95 percent CI 1.92, 34.08]). There was no significant change in clotting time, systolic blood pressure, or platelet count (reported qualitatively only).

Strength of evidence for systolic blood pressure was insufficient (Table 27).

### Ginseng

Three RCTs compared ginseng plus warfarin with warfarin alone (Table 28).69–71

Table 28 Strength of evidence for warfarin with or without ginseng—Intermediate outcomes

Cardiovascular Drugs(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect^*^
Warfarin
INR_peak_ | Moderate | Inconsistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive MD range 0.01–0.11 (95% CI −0.20 to −0.06, 0.08 to 0.42] M_ed_D−0.19 ( 95% CI −0.36, −0.07]
AUC of INR MD | Moderate | Inconsistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive MD range 0.03–0.49 (95% CI −39.10 to −0.28, 0.34 to 39.30] M_ed_D−0.43 ( 95% CI −1.00, −0.09]

Note:

* Range is provided when more than one study is being summarized.

Abbreviations: AUC of INR = area under the curve of the International Normalized Ratio; CI = confidence interval; GMR = geometric mean ratio; MD = mean difference; M_ed_D = difference of the medians; NA = not applicable; TG = triglycerides.

#### Ginseng Plus Warfarin Versus Warfarin Alone

Reported outcomes included INR,69–71, prothrombin time,69 platelet aggregation,71 and platelet count.69

Meta-analyses were not possible because of differences in patient populations (e.g., healthy versus postischemic stroke) and incompatible effect estimates (e.g., differences in means and differences in medians). One small study using Panax ginseng (1.5 g/day)in subjects with ischemic stroke reported no statistically significant differences in peak and AUC of INR, peak and AUC of prothrombin time, and platelet count.69 A study in young, healthy subjects, however, reported significantly lower peak INR and AUC of INR in the American ginseng (2 g/day) plus warfarin group.70 Another small study using single does of warfarin in 12 healthy males found no differences in AUC of INR and platelet aggregation after seven days pretreatment with ginseng (Panax ginseng, 3 g/day).71

Strength of evidence was graded as insufficient for peak INR and AUC of INR (Table 28).

### Hawthorn

In a randomized crossover trial, subjects were administered digoxin 0.25 mg/day for 10 days or digoxin 0.25 mg/day plus hawthorn 450 mg twice daily for 3 weeks.72 Subjects were tested with a standard 12-lead electrocardiogram for PR interval measurements. The difference between groups was statistically nonsignificant.

### Magnesium

Three RCTs investigated the use of oral magnesium with cardiovascular drugs: magnesium plus hydrochlorothiazide 73,74 and magnesium plus beta-adrenergic antagonists.42 Reported outcomes included total cholesterol, triglycerides, and systolic and diastolic blood pressure.

#### Magnesium Plus Hydrochlorothiazide Versus Hydrochlorothiazide Alone

In an eight week trial of 18 elderly subjects with benign essential hypertension taking magnesium (365 mg/day), nonsignificant differences were found in total cholesterol, triglycerides, and supine systolic and diastolic blood pressure.73 Nonsignificant differences for systolic and diastolic blood pressure (supine and standing) were also reported in a seven week trial using magnesium (365 mg/day) in 21 subjects with mild to severe uncomplicated essential hypertension.74 These two studies were meta-analyzed for supine systolic and diastolic blood pressure and the pooled estimates were statistically nonsignificant (Figures 7 and 8).73,74

Figure 7 Forest plot of supine systolic blood pressure for hydrochlorothiazide with or without magnesium (mmHg)

Figure 7 is a forest plot that displays effect estimates for supine systolic blood pressure in participants administered hydrochlorothiazide with or without magnesium. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −4.54 mmHg, lower bound 95% confidence interval −13.25, upper bound 95% confidence interval 4.16). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.92, p-value = 0.34).

Figure 8 Forest plot of supine diastolic blood pressure for hydrochlorothiazide with or without magnesium (mmHg)

Figure 8 is a forest plot that displays effect estimates for supine diastolic blood pressure in participants administered hydrochlorothiazide with or without magnesium. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −3.37 mmHg, lower bound 95% confidence interval −11.55, upper bound 95% confidence interval 4.81). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.42, p-value = 0.52).

Strength of evidence was graded as insufficient for systolic and diastolic blood pressure and triglyceride level (Table 29).

Table 29 Strength of evidence for cardiovascular drugs with or without magnesium—Intermediate outcomes

Cardiovascular Drug(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect^*^ MD (95% CI)
Hydrochlorothiazide
Blood pressure (mm Hg) | Moderate | Consistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Systolic Supine: Pooled −4.54 (−13.25, 4.16) Standing: 0 (−5.94, 5.94) Diastolic Supine: Pooled −3.37 (−11.55, 4.81) Standing: 1.00 (−8.84, 10.84)
Triglycerides (mg/dL) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive 1.77 (−103.19, 106.73)
Beta-adrenergic antagonists
Blood pressure (mm Hg) | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Systolic Supine: −4.26 (−12.56, 4.04) Standing: −4.34 (−13.90, 5.22) Diastolic Supine: −2.65 (−6.85, 1.55) Standing: −1.65 (−6.18, 2.88)

Note:

* Range is provided when more than one study is being summarized; pooled data is from meta-analysis of more than one study.

Abbreviations: CI = confidence interval; MD = mean difference; mm Hg = millimetres of mercury; NA = not applicable.

#### Magnesium Plus Beta-Adrenergic Antagonists Versus Beta-Adrenergic Antagonists Alone

In a crossover RCT, 39 subjects with essential hypertension on atenolol, metoprolol, pindolol, or propranolol were randomized to receive magnesium (365 mg/day) or placebo for eight weeks. Effect estimates for supine and standing systolic and diastolic blood pressures were statistically nonsignificant.42

Strength of evidence was graded as insufficient for systolic and diastolic blood pressure (Table 29).

### Niacin (Not More Than 250 mg)

One parallel-arm RCT described the use of niacin with propranolol in 16 subjects with Type II or Type IV hyperlipoproteinemia (Table 30).75 This study was rated as high risk of bias because groups were administered different dosages of propranolol (20 mg and 60 mg). Effect estimates for total cholesterol and triglycerides were statistically nonsignificant.

Table 30 Strength of evidence for propranolol with or without niacin—Intermediate outcomes

Cardiovascular Drug(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect MD (95% CI)
Triglycerides (mg/dL) | High | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive In Type II hyperlipoproteinemia: 8.40 (−114.22, 97.42) In Type IV hyperlipoproteinemia: −49.83 (−523.94, 424.28)

Abbreviations: CI = confidence interval; MD: mean difference; NA: not applicable

Strength of evidence was insufficient for triglycerides (Table 30).

### Omega-3 Fatty Acids/Fish Oil

Twenty-four RCTs, including 18 parallel-arm trials,40,44,50–53,55,56,76–78,91,92,94,98,151,152,163 and six crossover trials37,95–97,99,164 contributed evidence. The trials were conducted in North America,37,40,52,55,56,78,94,95,99,163 Australia,44,151,152,164 Europe,53,76,77,91,92,96–98 and Asia.50,51 The number of included participants in these trials ranged from 11^55^ to 658.^91^ The participants across studies received the following cardiovascular drugs: statins (atorvastatin, simvastatin, lovastatin),37,40,44,53,76,91,92,94–97,151,163 calcium channel blockers,50–52 niacin plus aspirin,78 ACE inhibitors,77,152 aspirin,98,99 beta-blockers,164 anticoagulation agents,55 and fenofibrates.56 In two trials, calcium channel blockers were used concomitantly with either aspirin,51 or aspirin plus dipyridamole.52 In most of the trials, participants were categorized as having unclear or mixed (different combinations of low, moderate/moderately high, and high) risk of coronary heart disease.165 The duration of treatment ranged from 2 weeks95,98 to 25 weeks.151,152 Further details on study, participants and treatment characteristics are presented in Appendix C.

Generally, most of these studies were reported to be double blind and had a moderate risk of bias across the outcomes of interest. In crossover trials, the adequacy of washout period was not clear for one trial,37 there was a potential of carryover in one trial (i.e., the treatment effect depended on the order of drug randomization),99 and no washout period was employed for another trial.164 The washout period length reported for three other trials was deemed to be adequate.95–97

Summary of findings and strength of evidence data are presented in Table 31. Meta-analyses were performed for the following outcome measures: HDL-C, LDL-C, total cholesterol, and triglycerides (Figures 9 to 14).

Table 31 Strength of evidence for cardiovascular drug(s) with and without omega-3 fatty acids—Intermediate outcomes

Cardiovascular Drug(s)/ Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect^*^
Statins
CRP44,158 (mg/L) | - | - | - | - | - | No difference Geometric mean difference: 1.14 (95% CI 0.6, 2.4) versus 1.80 mg/L (95% CI 1.3, 3.2)
HDL-C37,40,44,53,92,94,96,97,151,163 (mg/dL) | Moderate | Inconsistent | Indirect | Precise | Low | No difference Pooled mean difference: 2.26(95% CI −1.82, 6.34) 40,44,53,96,151,163
LDL-C37,40,44,53,92,94,96,97,151 (mg/dL) | Moderate | Inconsistent | Indirect | Precise | Low | No difference Pooled mean difference: 1.33 mg/dL (95% CI −3.56, 6.22)40,44,53,96,151
TC37,40,44,53,76,92,94,96,97,151 (mg/dL) | Moderate | Inconsistent | Indirect | Imprecise | Insufficient | Inconclusive Pooled mean difference: −7.06 mg/dL (95% CI −14.50, 0.37)40,44,53,96,151
TG40,76 | Moderate | Consistent | Indirect | Precise | Low | In favour of combination Pooled mean difference: −74.95 mg/dL (95% CI −95.80, −54.10)40,76
TG37,40,44,53,76,92,94,96,97,151,163 (mg/dL) | Moderate | Consistent | Indirect | Imprecise | Insufficient | Inconclusive Pooled mean difference: −17.88 mg/dL (95% CI −36.96, 1.21)44,53,96,151
Non-HDL-C 37,40,44,94,163 (mg/dL) | Moderate | Inconsistent | Indirect | Imprecise | Insufficient | Inconclusive −14.70 (95% CI −21.77, −7.62) 40 5.42 (95%CI −15.75, 26.59) 44 5.60 (95% CI −34.06, 45.26) 163 Median changes −40.2% vs −33.7%, p <0.001^94^ −40.0% vs −34.3%, p< 0.001^37^
TC/HDL-C ratio37,40,94,163 | - | - | - | - | - | Inconclusive −0.60 (95% CI −0.83, −0.36) 40 0.29 (95% CI −0.90, 1.48) 163 % change least squares means −6.5%, p<0.001^37^ Median change −38.3% vs −34.5%, p less than 0.001
LDL-C (<160/130/100 mg/dL) 94 | Moderate | NA | Indirect | Precise | Low | No difference RR 0.93 (95% CI 0.84, 1.03)
HDL-C (<190/160/130 mg/dL) 94 | Moderate | NA | Indirect | Precise | Low | No difference RR 1.00 (95% CI 0.91, 1.11)
Lipoprotein A 96 (mg/dL) | - | - | - | - | - | Inconclusive 2.00 (95% CI −34.40, 38.40)
Systolic Blood Pressure37,92,151 | Moderate | Inconsistent | Indirect | Precise | Low | In favor of supplement-CV drug combination −8.50 mm Hg (95% CI −16.33, −0.66) 92 Median change from baseline −5.0 vs. +0.3 mmHg 37 No difference (data not given) 151
Diastolic Blood Pressure37,92,151 (mm Hg) | Moderate | Inconsistent | Indirect | Precise | Low | No difference 0.20 (95% CI −4.76, 5.16) 92 No difference (data not given) 151 In favor of supplement-CV drug combination Median change from baseline −23.3 vs. −1.8 mmHg 37
Blood Coagulation 95 PT aPTT PA/AD PA/Collagen | - | - | - | - | - | No difference −0.10 sec (95% CI −0.28, 0.08) 0.10 sec (95% CI −0.62, 0.82) 1.10 % (95% CI −5.05, 7.25) 0.90 % (95% CI −5.70, 7.50)
Platelet Count76,95,97 | - | - | - | - | - | Inconclusive −9.82 10^3^/μL (95% CI −42.79, 23.15) 95 6.00 10^3^/μL (95% CI 1.74, 10.25)76 17.0% vs 20.0% change, p>0.05^97^
Bleeding Time97 | - | - | - | - | - | No difference 1.0% (95% CI -0.59, 2.59)
ACE inhibitors
TG77,152 mg/dL | Moderate | Inconsistent | Indirect | Imprecise | Insufficient | Inconclusive −38.6 (95% CI −160.62, 83.42) 77 −24.35 mg/dL (95% CI −45.31, −3.38) 152
Systolic Blood Pressure77,152 mm Hg | Moderate | Consistent | Indirect | Precise | Low | No difference Pooled mean difference: −0.51 (95% CI −10.59, 9.57)
Diastolic Blood Pressure77,152 mm Hg | Moderate | Consistent | Indirect | Precise | Low | No difference Pooled mean difference: −1.75 (95% CI −5.98, 2.48)
Urinary Protein excretion77 mg/d | - | - | - | - | - | In favor of supplement-CV drug combination −986.00 (95% CI −1763.43,−208.56)
≥50% Reduction in Proteinuria77 | - | - | - | - | - | In favor of supplement-CV drug combination RR 4.00 % of participants (95%CI 1.40, 11.30)
Fenofibrate
LDL-C56 | Moderate | NA | Indirect | Unclear | Insufficient | In favor of supplement-CV drug combination 48.20% vs 39.00% change, p=0.03
HDL-C56 | Moderate | NA | Indirect | Unclear | Insufficient | Inconclusive −1.90% vs 1.30% change, p>0.05
TC56 | Moderate | NA | Indirect | Unclear | Insufficient | Inconclusive −8.00% vs −5.10% change, p>0.05
TC/HDL-C56 | - | - | - | - | - | Inconclusive −4.80% vs −8.30% change, p>0.05
TG56 | Moderate | NA | Indirect | Unclear | Insufficient | Inconclusive −60.80% vs −53.80% change, p=0.059
Non-HDL-C56 | Moderate | NA | Indirect | Unclear | Insufficient | Inconclusive −8.20% vs −7.10% change, p>0.05
Incidence of hypertension (% of participants) | - | - | - | - | - | Inconclusive RR 0.98 (95% CI 0.14, 6.85)
Calcium Channel Blockers
LDL-C50 (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 0 (95% CI −94.30, 94.30)
HDL-C50 (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive −2.00 (95% CI −32.7, 28.70)
TC50 (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 5.00 (95% CI −91.30, 101.30)
TG50 mg/dL | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive −32.00 (95% CI −112.60, 176.60)
Calcium Channel Blockers + Aspirin
LDL-C51 mg/dL | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 1.00 (95% CI −10.90, 12.90)
HDL-C51 mg/dL | Moderate | NA | Indirect | Precise | Insufficient | Inconclusive −2.00 (95% CI −32.70, 28.70)
TC51 mg/dL | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 9.00 (95% CI −6.40, 24.40)
TG51 mg/dL | Moderate | NA | Indirect | Precise | Low | In favor of supplement-CV drug combination −54.00 (95% CI −94.1, −13.90)
Calcium Channel Blockers + Aspirin + Dipyridamole
LDL-C52 (mg/dL) | Moderate | NA | Indirect | Precise | Low | In favor of CV drug alone 21.00 (95% CI 3.30, 38.70)
HDL-C52 (mg/dL) | Moderate | NA | Indirect | Precise | Insufficient | Inconclusive 0 (95% CI −4.00, 4.00)
TC52 (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 19.00 (95% CI −1.70, 39.70)
TG52 (mg/dL) | Moderate | NA | Indirect | Precise | Low | In favor of supplement-CV drug combination −81.0 (95% CI −125.30, −36.70)
Platelet count52 (10^3^/μL) | - | - | - | - | - | Inconclusive −2.80 (95% CI −56.20, 0.20)
Niacin + Aspirin
LDL-C (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 17.00 (95% CI −6.60, 40.60)
HDL-C (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 1.00 (95% CI −13.20, 15.20)
TC (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive 9.00 (95% CI −19.10, 37.10)
TG (mg/dL) | Moderate | NA | Indirect | Imprecise | Insufficient | Inconclusive −94.00 (95% CI −196.80, 8.80)
Warfarin
INR | High | - | Indirect | - | - | No numeric data provided

Note:

* Range for mean difference (or risk ratio) given only when evidence consists of multiple studies that were not pooled. Intervention denotes dietary supplement arm; Control denotes placebo or no treatment arm. Range given if evidence consists of multiple studies.

Abbreviations: ACE = angiotensin-converting enzyme; aPPT = activated partial prothrombin time; CHD = coronary heart disease; CRP = C-reactive protein; HDL-C = high density lipoprotein-cholesterol; LDL-C = low density lipoprotein-cholesterol; NA = not applicable; NR = not reported; PA/AD = platelet aggregation/adenosine diphosphate PT = prothrombin time; RCT = randomized controlled trial; RR=relative risk; SBP = systolic blood pressure; TC = total cholesterol; TG = triglycerides; vs = versus; wk(s) = week(s); yr(s) = year(s).

Figure 9 Posttreatment HDL-C levels in subjects taking statins with or without omega-3 fatty acids/fish oils (mg/dL)

Figure 9 is a forest plot that displays effect estimates for HDL-C in participants administered statins with or without omega-3 fatty acids/fish oil. Seven studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = 1.70 mg/dL, lower bound 95% confidence interval −1.52, upper bound 95% confidence interval 4.92). Heterogeneity values were I2 = 55.92%, chi-squared = 14.13. p-value = 0.03)

Figure 10 Posttreatment LDL-C levels in subjects taking statins with or without omega-3 fatty acids/fish oils (mg/dL)

Figure 10 is a forest plot that displays effect estimates for LDL-C in subjects taking statins with or without omega-3 fatty acids/fish oil. Six studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means =−1.06 mg/dL, lower bound 95% confidence interval −5.28, upper bound 95% confidence interval 3.16). There was no heterogeneity (I2 = 16.86%, chi-squared = 4.43, p-value = 0.49).

Figure 11 Posttreatment total cholesterol levels in subjects taking statins with or without omega-3 fatty acids/fish oils (mg/dL)

Figure 11 is a forest plot that displays effect estimates for total cholesterol in subjects taking statins with or without omega-3 fatty acids/fish oil. Six studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −3.86 mg/dL, lower bound 95% confidence interval −10.69, upper bound 95% confidence interval 2.97). Heterogeneity was minimal (I2 = 35.42%, chi-squared = 7.19, p-value = 0.21).

Figure 12 Posttreatment triglyceride levels in subjects taking statins with or without omega-3 fatty acids/fish oils (mg/dL)

Figure 12 is a forest plot that displays effect estimates for triglycerides in subjects taking statins with or without omega-3 fatty acids/fish oil. Four studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −17.88 mg/dL, lower bound 95% confidence interval −36.96, upper bound 95% confidence interval 1.21). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.08, p-value = 0.99).

Figure 13 Posttreatment systolic blood pressure in subjects taking ACE inhibitors with or without omega-3 fatty acids/fish oils (mmHg)

Figure 13 is a forest plot that displays effect estimates for systolic blood pressure in subjects taking ACE inhibitors with or without omega-3 fatty acids/fish oil. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −0.51 mg/dL, lower bound 95% confidence interval −10.59, upper bound 95% confidence interval 9.57). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.01, p-value = 0.92).

Figure 14 Posttreatment diastolic blood pressure in subjects taking ACE inhibitors with or without omega-3 fatty acids/fish oils (mmHg)

Figure 14 is a forest plot that displays effect estimates for diastolic blood pressure in subjects taking ACE inhibitors with or without omega-3 fatty acids/fish oil. Two studies were pooled, yielding a statistically nonsignificant effect estimate (difference in means = −1.75 mg/dL, lower bound 95% confidence interval −5.98, upper bound 95% confidence interval 2.48). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.02, p-value = 0.89).

#### Omega-3 Fatty Acids/Fish Oils Plus Statins Versus Statins Alone

C-Reactive protein (CRP) was assessed in one placebo-controlled parallel arm randomized trial in participants at mixed CHD risk.44 The six week posttreatment geometric mean CRP levels were not different between the omega-3 fatty acids (4 g/day) plus atorvastatin and control (atorvastatin alone) groups.

High density lipoprotein-cholesterol. Posttreatment HDL-C was reported in 11 randomized trials.37,40,44,53,91,92,94,96,97,151,163 In five studies,44,53,96,151,163 the mean endpoint differences in HDL-C levels for participants with unclear or mixed CHD risk were not significantly different between the omega-3 fatty acids (2 to 10 g/day) combination and statins alone group. In one trial of participants at moderate CHD risk,40 the eight week posttreatment mean HDL-C level was significantly greater in the dietary supplement versus control group (MD 5.10 [95 percent CI 2.36, 7.83]). A meta-analysis based on the results from seven studies (participants with unclear or mixed CHD risk),40,44,53,91,96,151,163 indicated that the mean HDL-C levels did not differ between the omega-3 fatty acids (2.0 to 10.0 g/day) combination and statins alone group (Figure 9). Results from the remaining four trials reporting mean change,92 percent change,97 or percent median change37,94 were not consistent. Specifically, one trial of participants with mixed CHD risk reported a significant difference in the five week posttreatment mean change in favor of the omega-3 fatty acids (2 g/day) combination (difference in mean change 2.32 [95 percent CI 0.18, 4.45]).92 Similarly, two other trials of participants with unclear94 and mixed37 CHD risk reported significantly greater (i.e., improved) posttreatment percent increase in median HDL-C levels at 6 weeks (difference 7.2 percent, p 0.001),37 at eight weeks (difference of 2.4 percent, p less than 0.001)94 or at 16 weeks (difference of 6.3 percent, p less than 0.001)94 in favor of the dietary supplement intervention (4 g/day). In contrast, the percent change in HDL-C (from baseline) in one crossover trial of participants with mixed CHD risk was not significantly different between the dietary supplement (4 g/day) and control group at six weeks after the baseline (6.0 percent versus 14.0 percent).97

Overall, results indicated no difference in posttreatment HDL-C levels between the dietary supplement and control interventions (Table 31).

Low density lipoprotein-C. Posttreatment levels of levels of LDL-C were reported in 10 randomized trials.37,40,44,53,91,92,94,96,97,151 In six trials,40,44,53,91,96,151 the mean endpoint differences in LDL-C levels for participants with unclear or mixed CHD risk were not significantly different between the dietary supplement (2.0 to 9.2 g/day) and the control groups. Likewise, one trial found no significant difference in the mean change between the dietary supplement (2 g/day) and control groups (difference in mean change −5.84 mg/dL [95 percent CI −16.88, 5.20]).92

Our meta-analysis based on the results from 6 studies (participants with unclear or mixed CHD risk),40,44,53,91,96,151 indicated that the mean LDL-C levels did not differ between the intervention (2.0 to 9.2 g/day) and control groups (Figure 10).

Two other trials of participants with unclear94 and mixed37 CHD risk reported that there was no significant difference in either posttreatment percent change in least squares mean (difference of 1.30 percent, p 0.43)37 or percent change in median (difference at 8 weeks 2.2 percent, p 0.24; at 16 weeks 0.3 percent, p 0.64)94 in LDL-C levels for the supplement(4 g/day) versus control groups. The percent change in LDL-C (from baseline) in one crossover trial of participants at low CHD risk was not significantly different between the dietary supplement (6 g/day) and control group at six weeks (−39.0 percent versus −37.0 percent, p greater than 0.05).97

Total cholesterol. Posttreatment levels of TC were reported for 11 trials.37,40,44,53,76,91,92,94,96,97,151 The pooled results based on our meta-analysis of six trials in participants with unclear or mixed CHD risk 40,44,53,91,96,151 showed that the mean total cholesterol levels did not differ significantly between the intervention (2 to 9 g/day) and control groups (Figure 11; pooled mean difference: −3.86 [95 percent CI −10.69, 2.97])

In two other trials,76,92 the mean endpoint/mean change differences in total cholesterol levels for participants with unclear or mixed CHD risk were not significantly different between the dietary supplement and the control groups.

Similarly, one crossover trial97 using 6 g/day omega-3 fatty acids did not find a significant difference for mixed CHD risk participants in the posttreatment total cholesterol percent change from baseline between the two treatment groups (−31.0 versus −27.0, p greater than 0.05).

In one trial of participants with unclear CHD risk,40 the 8 week posttreatment mean total cholesterol level was significantly improved in the dietary supplement (4 g/day) versus control group (mean difference: −9.60 [95 percent CI −17.05, −2.14]). Two other trials reported significantly greater reductions in median total cholesterol percent change from baseline in the dietary supplement versus control groups for participants with mixed and unclear CHD risk (median percent change −2.7, p 0.006^37^ and −5.8, p value less than 0.001^94^).

One trial in participants with mixed CHD risk did not report numerical data.76

The wide confidence intervals around the pooled estimate rendered the results regarding posttreatment total cholesterol levels as inconclusive (Table 31).

Triglycerides. Posttreatment levels of TG were reported for 12 trials which included participants with unclear or mixed CHD risk.37,40,44,53,76,91,92,94,96,97,151,163

Initial pooling of six trials reporting posttreatment mean triglyceride levels revealed some degree of statistical heterogeneity (I^2^ 63.53 percent; Chi-squared statistic 15.95; p 0.01).40,44,53,76,96,151 After careful examination of the study factors that could potentially explain this heterogeneity, we found that in two studies40,76 which were conducted in specialty clinics, the participants’ baseline triglycerides levels were on average higher than those in other studies, thereby resulting in a greater magnitude of the observed mean differences in favor of the dietary supplement intervention (−73.50 mg/dL40 and −91.23 mg/dL76). The meta-analysis of the two studies in participants with higher baseline levels of TG (greater than 200 mg/dL) resulted in a significant pooled estimate of mean difference in favor of adding the supplement to statins (I^2^ 0 percent, Chi-squared statistic 0.21). (Table 31) The meta-analysis based the remaining four studies in participants with lower baseline levels of TG (less than 200 mg/dL) showed a non-significant pooled mean difference (Figure 12) with no significant heterogeneity (I^2^ 0 percent; Chi-squared statistic 0.08; p 0.99).44,53,96,151 Omega-3 fatty acid supplements ranged from 4 to 9.2 g/day, and participants were at mixed (moderate/moderately high44, or low/moderate/high96) or unclear CHD risk. Information on clinical settings for these studies was not reported.

Three trials reporting median37,94 or mean97 percent change from baseline in triglyceride levels showed significantly reduced (i.e., improved) levels for the dietary supplement versus control groups of participants with mixed (low/moderate/high) CHD risk, using omega-3 fatty acids (4 to 6 g/day)37,97 or unclear CHD risk, using omega-3 fatty acids (4 g/day).94 In contrast 4 month posttreatment median triglyceride levels were numerically similar between omega-3 fatty acids (2 g/day) plus statins versus statin alone group in participants with type II diabetes (97.4 mg/dL versus 106.2 mg/dL, p value was not reported) in one trial.91

The wide confidence intervals around the pooled estimate rendered the results with regards to posttreatment triglyceride levels between the dietary supplement and control interventions as inconclusive (Table 31).

Non-HDL-C. Posttreatment levels of non-HDL-C were reported for five trials, in which participants had mixed or unclear CHD risk.37,40,44,94,163 Dose of supplements used were 4 g/day in three trials,37,40,44,94 and 7.2 g/day in one trial.163 Of three trials reporting mean non-HDL-C levels,40,44,163 one trial in 254 participants with unclear CHD risk40 indicated significantly lower (i.e., improved) posttreatment mean non-HDL-C in the dietary supplement group compared with the control group, whereas the remaining two trials (44 participants in both trials) showed no significant between-group mean difference.44,163 The pooling of results from the three trials40,44,163 revealed statistical heterogeneity across the effect estimates (I^2^ 58.86 percent; Chi-squared statistic 4.96; p 0.08). There was no obvious explanation for this heterogeneity; the participants across these trials were of either unclear or mixed CHD risk. These studies were not pooled.

Trials reporting median percent change from baseline in non-HDL-C levels showed significantly greater (i.e., improved) reduction in non-HDL-C favoring the dietary supplement groups over the control groups in participants with unclear CHD risk94 and mixed CHD risk.37

The overall results regarding posttreatment non-HDL-C levels between the treatment groups were determined to be inconclusive (Table 31).

TC/HDL-C ratio. Posttreatment levels of the TC/HDL-C ratio were reported for four trials.37,40,94,163 Doses of supplement in these trials ranged from 4 to 7.2 g/day. Two trials in participants with unclear CHD risk 40,163 reporting posttreatment mean TC/HDL ratio levels yielded discrepant results, one in favor of the dietary supplement group,40 and the other in favor of neither group.163 This discrepancy in the results for TC/HDL-C ratio may have been due to differences between participants’ CHD risk across the studies. Based on the differences in CHD risk and the different directions of the effect estimates, it was decided not to pool these studies.

Two other trials in participants with mixed37 or unclear CHD risk94 reported significant differences in posttreatment percent change in least squares mean37 or percent change in median at eight weeks94 in the TC/HDL-C ratio, favoring the dietary supplement over the control intervention.

The overall results regarding differences in posttreatment TC/HDL-C ratio levels between the treatment groups were inconclusive (Table 31).

Predefined thresholds of LDL-C and non-HDL-C. The proportion of participants reaching these thresholds was reported for one 16 week, parallel arm trial in participants with unclear CHD risk.94 At the end of the treatment, there was no difference in the proportion of participants reaching pre-defined targets of either LDL-C (below 160, 130, or 100 mg/dL, or HDL-C (below 190, 160, or 130 mg/dL) between the supplement intervention (omega-3 fatty acids 4 g/day) and control groups (Table 31).

Lipoprotein A. Posttreatment levels of lipoprotein A were reported for one trial.96 In this crossover randomized trial, participants with familial hypercholesterolemia (mixed CHD risk) were treated over 4 weeks, for each treatment period. The difference in the 4 week posttreatment mean lipoprotein A levels between the omega-3 fatty acids (5.1 g/day) and control groups was not significant (Table 31).

Blood pressure. Systolic and diastolic blood pressure levels posttreatment were reported for four trials; three parallel arm91,92,151 and one crossover37 trial. In the first parallel arm trial92 participants with mixed CHD risk receiving omega-3 fatty acids (2 g/day) combined with statins (10 mg/day) for five weeks experienced significantly greater reductions in mean systolic blood pressure but not in diastolic blood pressure, compared with participants receiving statins alone. In two parallel arm trials with a treatment period of 16^91^ and 25 weeks151 in participants with unclear CHD risk there was no significant difference in the blood pressure between the omega-3 fatty acids(2 g/day in one trial, and 4 or 8 g/day in the other trial) in combination with statins versus statins alone. Statistical test results for the comparison were not provided.

In one crossover trial,37 participants with mixed CHD risk receiving omega-3 fatty acids (4 g/day) and statins (20 mg/day) experienced significantly greater median reductions from baseline in systolic and diastolic blood pressure compared with those receiving the control intervention.

We were unable to perform a meta-analysis given the lack of data151 and the differences in effect measures, reported as reductions in median37 and mean levels.92

The overall results showed lower posttreatment systolic blood pressure levels for the combination of omega-3 fatty acids and statins versus statins alone group (Table 31).

Blood coagulation. This outcome was reported for a crossover randomized trial in healthy participants. 95 After 2 weeks of treatment, there was no difference between the groups of omega-3 fatty acids (4 g/day) in combination with statins (80 mg/day) versus statins alone in the following blood coagulation parameters: prothrombin time, activated partial thromboplastin time, platelet aggregation with adenosine diphosphate, or platelet aggregation with collagen.

Platelet count. Posttreatment platelet count was reported for three trials; one parallel arm76 and two crossover trials.95,97 Study participants in these trials had mixed CHD risk (healthy volunteers, and participants with combined or familial hyperlipidemia). The differences between posttreatment mean change76,95 or percent change 97 in platelet counts between baseline and two to six weeks between the omega-3 fatty acids(4 to 6 g/day) and control groups was not significant. Two trials76,95 reporting posttreatment mean change in platelet count were not pooled because standard deviations were not reported for one study.95

Bleeding time. Posttreatment bleeding time was reported for a crossover randomized trial that included participants with mixed CHD risk (familial hyperlipidemia).97 There was no difference in percent change for bleeding time between the omega-3 fatty acids (6 g/day) and the control groups following 6 weeks of treatment.

#### Omega-3 Fatty Acids/Fish Oils Plus ACE Inhibitors Versus ACE Inhibitors Alone

Triglycerides. Posttreatment levels were reported for two parallel arm trials in participants with unclear CHD risk (Table 31).77,152 In a 25 week trial 77 the difference in mean triglyceride levels between the omega-3 fatty acids (5 g/day) and control groups was not significant. In contrast, in a 6 week trial152 the mean triglyceride reduction significantly favored the supplement (3 g/day) over the control group.152 These trials were not pooled due to differences in the reported effect measures.

The overall results regarding posttreatment triglyceride levels between the treatment groups were inconclusive.

Blood Pressure. Systolic and diastolic blood pressure levels posttreatment were reported for two parallel arm trials in participants with unclear CHD risk, with supplementation with omega-3 fatty acids (3 to 5 g/day)77,152 There was no significant between-group difference in either systolic blood pressure (mean difference 0 mm Hg77 and −1.00 mm Hg152) or diastolic blood pressure (−1.40 mm Hg 77 and −2.00 mm Hg152).

The pooled analysis of these trials77,152 indicated that there was no difference in either systolic (Figure 13) or diastolic (Figure 14) blood pressure between the intervention and control groups.

Urinary protein. Posttreatment data (protein excretion, and at least 50 percent reduction in proteinuria) was reported for one 25 week parallel arm trial in participants with unclear CHD risk.77 The participants in the omega-3 fatty acids (3 g/day) plus ACE inhibitors (10 mg/day ramipril plus 300 mg/day irbersartan) combination group had significantly reduced (i.e., improved) mean urinary protein excretion compared with participants in the ACE inhibitor alone (367 mg/day versus 1353 mg/day). Similarly, the proportion of participants who achieved at least 50 percent reduction in proteinuria was significantly greater (i.e., improved) in the supplement versus control group (80 percent versus 20 percent).

#### Omega-3 Fatty Acids/Fish Oils Plus Fenofibrate Versus Fenofibrate Alone

One study56 contributed evidence (Table 31). This was a parallel arm double blind placebo-controlled trial in 167 participants in whom the treatment allocation concealment was unclear (moderate risk of bias). Participants had unclear CHD risk and received treatment for eight weeks (4 g/day omega-3 fatty acids plus 130 mg/day fenofibrate versus 4 g/day placebo plus 130 mg/day fenofibrate). The percent change from baseline to week 8 was not significantly different between participants in the dietary supplement and control groups for HDL-C, total cholesterol/HDL-C ratio), total cholesterol, non-HDL-C, or triglycerides. In contrast, the percent change (i.e., reduction) from baseline in LDL-C levels was significantly greater in the dietary supplement versus control group. The incidence of hypertension was not significantly different between the two groups.

The overall results of this study on levels of LDL-C, HDL-C, TC/HDL-C ratio, total cholesterol, and non-HDL-C (reported as median percent change) were inconclusive.

#### Omega-3 Fatty Acids/Fish Oils Plus Calcium Channel Blockers Versus Calcium Channel Blockers Alone

One study50 contributed evidence (Table 31). This 16 week parallel arm open label active treatment controlled trial was in 22 participants at high CHD risk (variant angina). The supplement treatment (1.8 g/day omega-3 fatty acids plus 90 to 120 mg/day diltiazem versus diltiazem) allocation concealment was unclear (moderate risk of bias). The posttreatment mean difference in total cholesterol, LDL-C, HDL-C, and triglycerides were not significantly different between participants in the dietary supplement and control groups. Due to wide confidence intervals, these results were inconclusive.

#### Omega-3 Fatty Acids/Fish Oils Plus Aspirin and Calcium Channel Blockers Versus Aspirin and Calcium Channel Blockers Alone

One study51 contributed evidence (Table 31). This parallel arm single-blind (only assessors were blinded) active treatment (calcium channel blockers plus aspirin) controlled trial was in 107 participants for whom the randomization sequence was computer-generated and treatment allocation concealment was unclear (moderate risk of bias). Participants in this trial were at high CHD risk (pre-coronary angioplasty) and received their treatment for 6 weeks (3 g/day omega-3 plus calcium channel blockers and 150 mg/day aspirin versus calcium channel blockers and aspirin). The posttreatment mean triglycerides was significantly lower (i.e., improved) in the participants receiving the dietary supplement versus controls. The mean differences in total cholesterol, HDL-C, and LDL-C were not significantly different between the dietary supplement and control groups. The wide confidence intervals around these estimates rendered these results inconclusive (grade: insufficient).

#### Omega-3 Fatty Acids/Fish Oils Plus Calcium Channel Blockers, Aspirin, and Dipyridamole Versus Calcium Channel Blockers, Aspirin, and Dipyridamole

One study52 contributed evidence (Table 31). This parallel arm single-blind controlled trial was in 82 male participants for whom the randomization sequence was computer-generated and treatment allocation concealment was unclear (moderate risk of bias). All men in this trial were at high CHD risk (postcoronary angioplasty) and received their treatment for 12 weeks (3.2 g/day omega-3 plus calcium channel blockers,325 mg/day aspirin and 225 mg/day dipyridamole versus calcium channel blockers, aspirin and dipyridamole). Although the posttreatment mean LDL-C was significantly greater (i.e., worsened) in the participants receiving the dietary supplement versus controls, the mean triglyceride levels were significantly lower (i.e., improved) in the dietary supplement versus the control group. HDL-C, total cholesterol, and platelet count were not significantly different. The wide confidence intervals around these estimates rendered these results inconclusive (grade: insufficient).

#### Omega-3 Fatty Acids/Fish Oils Plus Niacin (More Than 250 mg), and Aspirin Versus Niacin (More Than 250 mg), and Aspirin

One study78 contributed evidence (Table 31). This parallel arm placebo controlled active treatment (niacin plus aspirin) trial was in 14 participants for whom the randomization sequence and treatment allocation concealment were unclear (moderate risk of bias). The participants in this trial had unclear CHD risk (atherogenic dyslipidemia) and received their treatment for 12 weeks (4 g/day omega-3 plus 500 to 3000 mg/day niacin plus 325 mg/day aspirin versus niacin and aspirin).

The posttreatment mean differences in total cholesterol, HDL-C, LDL-C and triglycerides were not significantly different between the dietary supplement and control groups.

#### Omega-3 Fatty Acids/Fish Oils Plus Aspirin Versus Aspirin Alone

In two trials in healthy participants with low or mixed CHD risk, a single dose of aspirin (325 mg99 or 100 mg98) was administered following two to three weeks of omega-3 fatty acids (8 to 10 g/day) or placebo pre-treatment.

#### Omega-3 Fatty Acids/Fish Oils Plus Beta-Adrenergic Antagonists Versus Beta-Adrenergic Antagonists

Blood Pressure. Systolic and diastolic blood pressure change posttreatment was reported for one trial.164 This double-blind crossover trial was in 25 participants with unclear CHD risk, on beta-blocker monotherapy who were randomized to receive omega-3 fatty acids (4 g/day) or placebo for 6 weeks. No washout period was reported for this trial. The data for this study were not reported clearly, which precluded meaningful synthesis of the evidence.

#### Omega-3 Fatty Acids/Fish Oils Plus Warfarin Versus Warfarin Alone

One 4 week study55 contributed evidence. This was a parallel double blind (blinding status of participants, care providers, or study assessors was unclear), placebo-controlled trial in 11 participants with unclear CHD risk, for whom the randomization sequence and treatment allocation concealment were unclear (high risk of bias – there was a baseline between-group imbalance in gender and age). Treatment was 3 g/day or 6 g/day omega-3 fatty acids plus warfarin versus placebo plus warfarin. There was no significant difference in posttreatment INR values between the dietary supplement and control groups (p 0.41; no additional numerical data were provided).

Applicability. Statin combinations were examined in populations with 22 to 100 percent males, with unclear to mixed CHD risk, and mean age ranging from 30 years to 63 years. ACE inhibitors were examined in populations with 40 to 85 percent males, with unclear or high CHD risk, and mean age 40 years to 60 years. Calcium channel blockers plus aspirin plus dipyridamole were examined in a male population, with high CHD risk, and mean age 56 years. Trial duration ranged from 4 to 25 weeks.

### Vitamin E

Ten RCTs and one controlled clinical trial examined the use of Vitamin E with cardiovascular drugs. Subjects were concomitantly taking antiplatelet agents (aspirin or ticlopidine)49,80, furosemide 81, gemfibrozil79, nifedipine82, or statins.46,83–87

#### Vitamin E Plus Antiplatelet Agents Versus Antiplatelet Agents Alone

Two parallel-arm RCTs examined the effect of concomitant use of vitamin E and antiplatelet agents.49,80 In comparison with no treatment, 6 weeks of treatment with vitamin E (400 to 450 IU/day) was not found to effect total cholesterol in atherosclerotic plaque in 16 participants with high CHD risk taking aspirin or ticlopidine80. No changes in serum total cholesterol and triglyceride levels at followup were noted (reported qualitatively only). These results were potentially impacted by Type II error due to small sample size.

Platelet aggregation was assessed in a trial comparing vitamin E (400 IU/day) plus aspirin with aspirin alone in elderly, primarily white, subjects with transient ischemic attack, minor stroke, or residual neurologic deficits (unclear CHD risk).49 Treatment was administered for 2 years. Platelet adhesion to collagen III was significantly decreased by vitamin E supplementation.

Strength of evidence was insufficient for triglycerides (Table 32).

Table 32 Strength of evidence for cardiovascular drug(s) with and without vitamin E—Intermediate outcomes

Cardiovascular Drugs(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect^*^ MD (95% CI)
Antiplatelet Agents
Triglycerides | Moderate | NA | Indirect (surrogate) | NA | Insufficient | Inconclusive No changes observed at end of follow-up (reported qualitatively only)
Platelet adhesion to collagen III (/cm^2^ × 10^5^) | - | - | Indirect (surrogate) | - | - | In favor of combination treatment MD −1.70 (−2.06, −1.34]).
Furosemide
Blood pressure | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Systolic −3.00 mmHg (−7.69, 1.69) Diastolic −2.00 mmHg (−6.36, 2.36)
Nifedipine
Blood pressure | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Systolic −2.00 mmHg (−19.55, 15.55) Diastolic −1.00 mmHg (−3.79, 1.79)
LDL-C | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment −39.83 mg/dL (−71.29, −8.37)
HDL-C | Moderate | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive 4.26 mg/dL (−2.02, 10.54)
Triglycerides | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment −23.91 mg/dL (−35.89, −11.93)
Total cholesterol(TC) (mg/dL) | - | - | Indirect (surrogate) | - | - | In favor of combination treatment MD −35.96 (−46.96, −24.96),
Gemfibrozil
Blood Pressure | High | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Systolic 7.00 mmHg (−14.07, 28.07) (elderly) −3.00 mmHg (−22.46, 16.46) (young) Diastolic 4.00 mmHg (−11.29, 19.29) (elderly) −1.00 mmHg (−13.00, 11.00) (young)
LDL-C | High | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive 6.96 (−132.08, 146.00) (elderly) −4.25 (−16.85, 8.35) (young)
HDL-C | High | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive 0 (−4.42, 4.42) (elderly) 6.19 (−1.28, 13.66) (young)
Triglycerides | High | NA | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive −23.91 (−336.44, 288.62) (elderly) −7.97 (−45.23, 29.29) (young)
Statins
HDL-C | Moderate | Inconsistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Pooled MD 1.31 mg/dL (−3.04, 5.67)
LDL-C | Moderate | Consistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Pooled MD −9.46 mg/dL (−26.81, 7.89)
Triglycerides | Moderate | Consistent | Indirect (surrogate) | Imprecise | Insufficient | Inconclusive Pooled MD 1.23 mg/dL (−4.42, 6.89)

Note:

* Range for mean difference (or risk ratio) given only when evidence consists of multiple studies that were not pooled. Intervention denotes dietary supplement arm; Control denotes placebo or no treatment arm. Range given if evidence consists of multiple studies.

Abbreviations: CI = confidence interval; HDL-C = high density lipoprotein-cholesterol; LDL-C = low density lipoprotein-cholesterol; MD = mean difference; NA = not applicable.

#### Vitamin E Plus Furosemide Versus Furosemide Alone

One small parallel-arm RCT of 24 participants examined the concomitant use of Vitamin E and furosemide.81 Participants were randomized to receive either Vitamin E (600 mg/day) and furosemide (25 mg/day) or furosemide (25 mg/day) with placebo for 4 weeks. No significant differences were found in systolic and diastolic blood pressure. Strength of evidence for blood pressure was insufficient (Table 32).

#### Vitamin E Plus Nifedipine Versus Nifedipine Alone

One small crossover RCT in 30 participants at high CHD risk examined vitamin E (900 mg/day) plus nifedipine versus placebo plus nifedipine.82 Nifedipine long-acting formulation (average dose 88 plus/minus 11 mg/day) and Vitamin E were administered for four months.

Supplementation with Vitamin E was found to significantly lower total serum cholesterol, LDL-C, and triglycerides. HDL-C was slightly raised by administration of vitamin E, but the estimate was not statistically significant. There were no statistically significant differences in systolic and diastolic blood pressure.

The strength of evidence was insufficient for systolic and diastolic blood pressure, and HDL-C. Strength of evidence for improvement in LDL-C and triglyceride levels with combination treatment was low (Table 32).

Applicability. This study recruited elderly (mean age 73.8 plus/minus2.1 years), moderately obese subjects with stable effort angina and high CHD risk.

#### Vitamin E Plus Gemfibrozil Versus Gemfibrozil Alone

The combination of vitamin E (600 mg/day) and gemfibrozil was assessed in one controlled clinical trial in 67 participants.79 Subjects were hyperlipidemic and were divided into young (mean age 29.5 plus/minus 4.9 years) and elderly (mean age 71.5 plus/minus 3.6 years) groups. No statistically significant effects were observed in lipid parameters or blood pressure. Effect estimates had very wide 95 percent confidence intervals, so this study was underpowered to detect statistically significant results. Strength of evidence for blood pressure and lipid parameters was insufficient (Table 32).

#### Vitamin E Plus Statins Versus Statins Alone

Six RCTs addressed combined use of vitamin E (400 to 1000 U/day) and statins, including atorvastatin87, simvastatin83–86, and pravastatin46. All studies included subjects with hypercholesterolemia. In some studies, subjects also had additional conditions, such as diabetes87 and vascular disease.86

Lipid parameters were reported in all studies. Meta-analyses of total cholesterol, LDL-C, HDL-C, and triglycerides were undertaken for four trials.83–86 Two trials could not be meta-analyzed because different effect estimates were reported (i.e., one trial reported serum lipid parameters in a qualitative manner only87 and one trial reported lipid parameters as percent change from baseline46).

One study reported nonsignificant differences in cholesterol and triglyceride levels in non-HDL subfraction for combination vitamin E plus atorvastatin.87 Another study reported nonsignificant differences for percent change in baseline for total cholesterol, LDL-C, HDL-C, and triglycerides for combination vitamin E plus pravastatin.46

The four trials that were pooled involved administration of vitamin E with simvastatin (total sample size 106).83–86 Dosages of vitamin E and simvastatin ranged from 400 to 1000 U/day and 10 to 40 mg/day respectively. The pooled effect estimates for total cholesterol, LDL-C, HDL-C, and triglycerides were all statistically nonsignificant (Figures 15–18). Heterogeneity was minimal for all pooled estimates except for LDL-C (I^2^ 64.6 percent, p-value 0.04). The observed heterogeneity could not be explained by variation of doses of supplement or cardiovascular drug. The strength of evidence was insufficient for LDL-C, HDL-C, and triglycerides (Table 32).

Figure 15 Forest plot of total cholesterol for statins with or without vitamin E (mg/dL)

Figure 15 is a forest plot that displays effect estimates for total cholesterol in subjects taking statins with or without vitamin E. A total of four studies contributed evidence. The pooled estimate was statistically nonsignificant (difference in means = −4.87 mg/dL, lower bound 95% confidence interval 16.33, upper bound 95% confidence interval 6.59). Heterogeneity was minimal (I2 = 18.0%, chi-squared = 3.66, p-value = 0.30).

Figure 16 Forest plot of LDL-C for statins with or without vitamin E (mg/dL)

Figure 16 is a forest plot that displays effect estimates for LDL-C in subjects taking statins with or without vitamin E. A total of four studies contributed evidence. The pooled estimate was statistically nonsignificant (difference in means = −9.46 mg/dL, lower bound 95% confidence interval −26.81, upper bound 95% confidence interval 7.89). Heterogeneity was present (I2 = 64.6%, chi-squared = 8.49, p-value = 0.04).

Figure 17 Forest plot of HDL-C for statins with or without vitamin E (mg/dL)

Figure 17 is a forest plot that displays effect estimates for HDL-C in subjects taking statins with or without vitamin E. A total of four studies contributed evidence. The pooled estimate was statistically nonsignificant (difference in means = 1.31mg/dL, lower bound 95% confidence interval −3.04, upper bound 95% confidence interval 5.67). There was no heterogeneity (I2 = 0.0%, chi-squared = 1.11, p-value = 0.78).

Figure 18 Forest plot of triglyceride levels for statins with or without vitamin E (mg/dL)

Figure 18 is a forest plot that displays effect estimates for triglyceride levels in subjects taking statins with or without vitamin E. A total of four studies contributed evidence. The pooled estimate was statistically nonsignificant (difference in means = 1.23 mg/dL, lower bound 95% confidence interval −4.42, upper bound 95% confidence interval 6.89). There was no heterogeneity (I2 = 0.0%, chi-squared = 2.20, p-value = 0.53).

Other reported outcomes included C-reactive protein, prothrombin time, and platelet count. In a study of middle aged hypercholesterolemic subjects at low CHD risk, a statistically significant difference for C-reactive protein in favor of Vitamin E plus simvastatin was found (MD −0.40 mg/L (95 percent CI −0.66, −0.14]).85 In another study of hypercholesterolemic subjects, no differences were found in prothrombin time and platelet count between Vitamin E plus pravastatin and pravastatin alone (reported qualitatively only).

### Vitamin K

#### Vitamin K Plus Coumarin Derivatives Versus Coumarin Derivatives Alone

One parallel-group RCT examined the effect of concomitant use of Vitamin K (5 mL volume per dose with concentration of 30 μg/mL vitamin K) and warfarin.41 One cohort study was also identified that assessed whether vitamin K intake in subjects taking anticoagulants is associated with subtherapeutic INR.150 The results of this study have not been included in the evidence synthesis as it added no further insights to the existing randomized trial.

The percentage of time that INR remained in the therapeutic range was reported (defined as INR within 0.5 of 2.0 to 3.0). Patients receiving Vitamin K stayed in the INR therapeutic range for a statistically significant longer percentage of time than patients who received warfarin alone.

INR control was also examined in terms of the standard deviation of the INR41 and the number of participants achieving improved INR control compared with six months prior to study.41 Vitamin K was found to increase stability of anticoagulation treatment (Table 33). Furthermore, the number of participants achieving stable INR was higher in combination with warfarin (RR 2.56 [95 percent CI 1.24, 5.28]).41

Table 33 Strength of evidence for coumarin derivatives with and without vitamin K—Intermediate outcomes

Cardiovascular Drugs(s)/Outcome | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect^*^ (95% CI)
% time in INR therapeutic range | Moderate | Consistent | Indirect (surrogate) | Precise | Low | In favor of combination treatment MD 9% (1.42, 16.57)
SD of INR | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment MD −0.12 (−0.20, −0.04)
N achieving INR control | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment N achieving INR control RR 1.30 (1.04, 1.62)
N achieving stable INR | Moderate | NA | Indirect (surrogate) | Precise | Low | In favor of combination treatment N achieving stable INR RR 2.56 (1.24, 5.28)

Note:

* Range for mean difference (or risk ratio) given only when evidence consists of multiple studies that were not pooled. Intervention denotes dietary supplement arm; Control denotes placebo or no treatment arm. Range given if evidence consists of multiple studies.

Abbreviations: CI = confidence interval; INR = International Normalized Ratio; MD = mean difference; N = number; NA = not applicable; SD = standard deviation.

Strength of evidence for the statistically significant INR measures was low (Table 33).

Applicability. Participants with atrial fibrillation being anticoagulated with warfarin for thromboembolic prophylaxis, but with unstable INR control.41 The trial was of 6 months duration.

### Key Question 2a Do the effect estimates of intermediate cardiovascular outcomes vary by age, ethnicity, gender, or health status?

No studies for any supplement-drug combination of interest precluded exploration of heterogeneity in the effect estimates across preidentified subgroups for intermediate outcomes.

### Key Question 2b Is there a measurable interaction between cardiovascular drugs and dietary supplements for intermediate cardiovascular outcomes?

Two studies contributed to the evidence regarding statistical interaction between cardiovascular drugs and dietary supplements for this section.44,78 One study assessed statistical interaction using general linear modeling.44 No significant interactions were observed between the combination of omega-3 fatty acids (4 g/day) and statins with regards to changes in lipid profile (HDL-C, LDL-C, total cholesterol, triglycerides, non-HDL-C) in 52 obese men with dyslipidaemia and insulin resistance (moderate/moderately high risk for CHD).44 Authors of another trial78 conducted a formal assessment of statistical interaction using ANOVA and found that the decrease in triglyceride levels resulting from the combination of omega-3 fatty acids (4 g/day) and niacin was more than twice the additive effect of either therapies alone in 29 participants with atherogenic dyslipidemia (unclear CHD risk).

### Main Points for Key Question 2—Intermediate Outcomes

We compared a dietary supplement coadministered with a cardiovascular drug(s), with the cardiovascular drug(s) alone (or in conjunction with another supplement) to investigate comparative intermediate cardiovascular efficacy outcomes, subgroup effects and statistical interactions.

- Fifty-seven RCTs, two controlled clinical trials and no observational studies addressed this Key Question.
- No study addressed the following outcomes: incidence of metabolic syndrome; carotid-intima media thickness; and change in 10-year Framingham risk profile.
- Exploration of heterogeneity for preidentified subgroups (e.g., males/females, ethnic groups, and the elderly) was not possible due to sparse data found for each supplement-drug combination of interest.
- No evidence was found for intermediate outcomes for the following supplements in combination with cardiovascular drugs: red yeast rice extract; resveratrol; vitamin A; or vitamin D with or without calcium.
- Most evidence was from small, underpowered RCTs that provided inconclusive results.
- The strength of evidence for gradable outcomes was generally insufficient due to inconsistencies in the treatment effect direction and the wide confidence interval compatible to potential for both clinical benefits and harms.
- Low grade evidence indicated improvement in a few intermediate outcomes in the following dietary supplement plus cardiovascular drug versus cardiovascular drug alone:
  ○ HDL-C: garlic plus nitrates, garlic plus warfarin; coenzyme Q10 plus fenofibrate
  ○ Triglyceride: garlic plus nitrates, omega-3 fatty acids in addition to calcium channel blockers and aspirin, calcium channel blockers, statins plus aspirin and dipyridamole (in participants with mean baseline TG levels of 200 mg/dL or higher); vitamin E plus nifedipine;
  ○ LDL-C: vitamin E plus nifedipine;
  ○ Systolic blood pressure: omega-3 fatty acids plus statins;
  ○ INR (percentage of time INR in therapeutic range, proportion of subjects achieving INR, proportion of subjects with stable INR): vitamin K plus anticoagulant (warfarin, coumarin derivatives);
  ○ Bleeding time: Ginkgo biloba plus cilostazol;
  ○ Coronary artery calcification (volume calcium score): Ginkgo biloba plus cilostazol;
  ○ Proteinuria (participants with 50 percent or greater reduction): omega-3 fatty acids plus ACE inhibitors.
- Low grade evidence indicated no difference between omega-3 fatty acids plus statins compared with statins alone in the following measures: HDL-C, LDL-C, achieving LDL-C and HDL-C targets; diastolic blood pressure; C-reactive protein; blood coagulation parameters; and bleeding time.
- Evidence was insufficient (type II error could not be excluded due to the low power of studies) for the following supplement plus cardiovascular drug combinations compared with the cardiovascular drug alone:
  ○ lipid profile: coenzyme Q10 plus statins; coenzyme Q10 plus fenofibrate; garlic plus statins and aspirin; Ginkgo biloba plus aspirin; magnesium plus hydrochlorothiazide;omega-3 fatty acids plus fenofibrates;omega-3 fatty acids plus calcium channel blockers;omega-3 fatty acids plus niacin and aspirin;omega-3 fatty acids plus aspirin; vitamin E plus gemfibrozil, or statins;
  ○ HDL-C: vitamin E plus nifedipine;omega-3 fatty acids plus calcium channel blockers and aspirin, calcium channel blockers plus aspirin and dipyridamole;
  ○ Triglycerides: niacin plus propranolol; garlic plus nitrates;omega-3 fatty acids plus ACE inhibitors; omega-3 fatty acids plus statins (in participants with lower baseline TG levels); magnesium-hydrochlorothiazide; magnesium plus beta-adrenergic antagonists; vitamin E plus antiplatelet agents;
  ○ LDL-C: omega-3 fatty acids plus calcium channel blockers and aspirin;
  ○ Blood pressure: garlic plus warfarin; Ginkgo biloba plus aspirin, or antiplatelet thienopyridines, or cilostazol; magnesium plus hydrochlorothiazide, or beta-adrenergic antagonists;omega-3 fatty acids plus aspirin, or beta-blockers; vitamin E plus furosemide; vitamin E plus nifedipine; vitamin E plus gemfibrozil;
  ○ INR: Echinacea plus warfarin; garlic plus warfarin; ginger plus warfarin; Ginkgo biloba plus warfarin; ginseng plus warfarin (peak INR, AUC_INR_); and omega-3 fatty acids plus warfarin.
- No statistical interaction was found for combination of omega-3 fatty acids plus statins for lipid parameters HDL-C, LDL-C, total cholesterol, triglycerides, and non-HDL-C.
- A positive interaction was found for the combination of omega-3 fatty acids plus niacin and aspirin for triglycerides. The decrease in triglycerides resulting from combination treatment was more than twice the additive effect of the therapies alone.

## Key Question 3 In adults taking cardiovascular drugs, what are the effects of concomitant use of specific dietary supplements (when compared to cardiovascular drugs alone or cardiovascular drugs and a different dietary supplement(s]) on clinical or intermediate harms outcomes (e.g., organ toxicity, serious adverse events, withdrawal due to adverse events)

a. Do the effect estimates of harms outcomes vary by age, ethnicity, gender, or health status?
b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for harms outcomes?

### Overview

A total of 58 unique studies were included for Key Question 3 (Table 34).39,44,46,47,49,51–53,55,56,78,81–84,86,87,91,92,96,97,99,100,36–38,40–42,48,54,57–69,71–77,88–90,93–95,98

Table 34 Overview of availability of evidence for harms outcomes—Key Question 3

Dietary Supplement | N of Studies Included | Cardiovascular Drug(s) | Study Design(s)
Coenzyme Q10 | 5^38,54,57,58,89^ | Atorvastatin, simvastatin, fenofibrate, ACE-Inhibitors | 4 Parallel RCT, 1 crossover RCT
Echinacea | 1^59^ | Warfarin | Crossover RCT
Garlic | 4^60–63^ | Warfarin, nitrates, statin + aspirin | 3 Parallel RCT, 1 crossover RCT
Ginger | 1^64^ | Warfarin (single dose) | 1 Crossover RCT
Ginkgo biloba | 7^48,64–68,90^ | Warfarin, aspirin, aspirin and/or pentoxiphylline, digoxin, nitrates, statin + aspirin, ticlopidine | Parallel RCT (2), crossover RCT (5)
Ginseng | 3^69–71^ | Warfarin | 1 crossover, and 2 parallel RCTs
Hawthorne | 1^72^ | Digoxin | Crossover RCT
Magnesium (oral) | 3^42,73,74^ | Hydrochlorthiazide, metoprolol, atenolol, pindolol, propanolol | 2 Parallel RCTs and 1 crossover RCT
Niacin (≤ 250 mg/d) | 1^75^ | Propanolol | Crossover RCT
Omega-3 fatty acids (or fish oils) | 22^36,37,40,44,47,51–53,55,56,76–78,88,92–99^ | Statins; Aspirin; Aspirin + Clopidogrel; Aspirin + Dipyridamole + Ca Channel Blockers; Warfarin; Ramipril and/or irbesartan; Fenofibrate | 13 Parallel RCT, 8 crossover RCT, 1 retrospective cohort
Vitamin E | 10^39,46,49,81–84,86,87,100^ | Aspirin, simvastatin, atorvastatin, pravastatin, furosemide | 8 Parallel RCT and 2 crossover RCT
Vitamin K | 2^41,143^ | Warfarin, phenprocoumon | Parallel RCT

Abbreviations: ACE-I = Angiotensin-converting enzyme inhibitors; N = total number; RCT = randomized controlled trial

One of the included studies was a retrospective cohort study,88 while the rest were RCTs. Summary characteristics of the study and population is shown in Table 35.

Table 35 Summary of study characteristics—Key Question 3

Study Characteristic | Distribution
Sample CHD risk | Low 17.5% Moderate to moderately high 1.8% High 22.8% Mixed 25.3% Unclear 32.6%
Geographical region | North America 19.3% Europe 28.1% Australia/New Zealand 5.3% East Asia 4.3% Rest of Asia 5.3% NR/Other 37.8%
Setting | Primary care/community 36.1% Specialty care 24.6% NR 39.4%
Duration | Mean 21 weeks, range 1 day to 10 years
Total N randomized | Mean, 775.2, range 8 to 19,934, total across studies = 23,474
Age | Mean age 55 years
Gender | Ten trials exclusively in males,44,52,59,61,64,65,67,68,71,98 and two in females.39,100 Of the mixed gender studies, 77% included females representing less than 40% of study sample.
Race/Ethnicity | Seventeen studies reported race/ethnicity distribution. Eight included a majority of Caucasians.36,37,39–41,49,65,74 Two studies included all Asians,57,68 and two majority Hispanics.55,95

One study examined the statistical interaction between vitamin E and aspirin 100 on harms. The characteristics of included studies are summarized in Table 34. Overall, the studies were generally of moderate risk of bias across all gradable harms, as summarized in Table 36. The harms outcomes examined across the included studies ranged from minor (e.g., flatulence) to serious (e.g., major bleeding). Although a higher proportion of the harms outcomes were reported as continuous data rather than dichotomous data, the dichotomous outcomes were the focus of the present work, as these are the most suitable type of data for examining harms. A carryover effect was not a major concern in the crossover trials because most of the studies incorporated adequate washout periods in their design – well over five times the half-life of the drug supplement under investigation. However, a carryover effect may have influenced the results of 5 of the included crossover studies because it was not clearly reported,37 the washout period was only one week,99 or there was no washout period.42,75,86 Detailed study characteristics and data from each of the included studies are available in Appendix C. For each supplement examined, we compared the different cardiovascular drug and supplement combination(s) versus the cardiovascular drug alone. For most supplement-cardiovascular drug related harms outcomes, data were either absent or too sparse with occasional events, precluding meaningful synthesis (Appendix C). Where subgroup analysis could be carried out, we report subgroup results as an additional consideration under the corresponding supplement.

Table 36 Risk of bias and potential for conflict of interest—Key Question 3

Item
All RCTs (N = 57) | Yes | No | Unclear
Adequate generation of allocation sequence | 23 | 0 | 77
Allocation concealment | 9 | 0 | 91
Comparability of groups | 49 | 18 | 33
Purity of supplement | 83 | 14 | 4
Blinding of allocated intervention | 26 | 25 | 49
Adequately addressed missing data | 61 | 4 | 35
Freedom from potential for conflict of interest | 23 | 33 | 44
Crossover RCTs (N = 21)
Suitability of crossover design for the study condition | 100
Freedom from carryover effect | 19.0 | 71.4 | 9.5
Appropriateness of statistical analysis for crossover design | 23.8 | 14.3 | 61.9
Comparability of groups between periods 1 and 2 | 9.5 | 0.0 | 90.5
Freedom from bias introduced by dropouts | 76.2 | 9.5 | 14.3

Abbreviations: N = total number; RCTs = randomized controlled trials.

No data were found for the following supplements: red yeast rice, resveratrol, vitamin A, vitamin D (with or without calcium).

### Coenzyme Q10

Four RCTs examined coenzyme Q10 plus statins, fenofibrate or angiotensin-converting enzyme (ACE) inhibitors versus statins, fenofibrate, or ACE inhibitors alone.38,54,57,58 One study examined coenzyme Q10 plus statins compared with vitamin E plus statins.89 The included patients ranged from those with ischemic or idiopathic dilated cardiomyopathy,54 or diabetes, 58 to individuals with myalgia,38 or myopathic pain.89 The majority of studies were parallel RCTs (one crossover RCT54) with moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes.

#### Coenzyme Q10 Plus Statins Versus Statins Alone

Insufficient evidence was noted across all of the gradable clinical adverse events and organ toxicity outcomes for coenzyme Q10 plus statins versus statins alone, including serious adverse events,57 withdrawal due to adverse events,38,57 hepatoxicity (elevated alanine transaminase,38 or elevated aspartate aminotransferase38), and renal dysfunction (abnormal glomerular filtration rate38) (Table 36). None of the included studies examined the gradable outcome bleeding. One RCT examined adverse events in general and zero events were observed.57 One small pilot RCT examined myalgia in 44 participants using visual Analogue Scale and did not find a statistically significant difference between coenzyme Q10 (200 mg/day) plus statins (simvastatin 10 to 40 mg/day) versus statins alone (median 6.0 [inter quartile range 2.1, 8.8] vs. 2.3 [interquartile range 0.0, 12.8], p 0.63).38 Similarly, in this trial there was no statistically significant difference between coenzyme Q10 plus statin and statin alone groups in proportion of patients tolerating statin (16/22 versus 13/22, p 0.47; RR 1.23, 95 percent CI 0.80, 1.90). Note that this RCT38 was powered to detect a 9 mm difference in myalgia scores between treatment groups. Study designers assumed that less than 10 percent of patients would tolerate high dose simvastatin (40 mg/day) alone compared with 50 percent tolerating combined therapy, and that 50 percent of patients would tolerate lower dose simvastatin (10 mg/day or more) compared with greater than 90 percent tolerating combination therapy at the comparable simvastatin dose.

Two RCTs examined fasting blood glucose as a continuous outcome; no differences were observed with 100 mg57 or 200 mg58 of coenzyme Q10 added to atorvastatin,57 or fenofibrate58 versus these cardiovascular drugs alone. Other continuous outcomes reported for the statins included myoglobin,57 creatine kinase (CK), or creatine phosphokinase (CPK);57 no statistically significant differences were observed.

#### Coenzyme Q10 Plus Statins Versus Vitamin E Plus Statins

One small pilot RCT found a higher frequency of decreased myopathic pain in the coenzyme Q10 (100 mg/day) plus statin group (16/18) versus the vitamin E (400 IU/day) plus statin group (3/14), and the relative risk (RR) was 4.18 (95 percentCI1.50, 11.46).89 Similarly, significantly lower pain severity scores on the four pain intensity items of the Brief Pain Inventory Questionnaire,(MD −1.76 (95 percent CI −2.93, −0.58]) and lower average pain interference scores on the seven items of the Questionnaire (MD −1.43 (95 percent CI −2.76, −0.10]) were observed in the coenzyme Q10 plus statins versus the vitamin E plus statins group.89 No statistically significant differences were observed in phosphokinase levels. Participants in this trial used various type of statins in varying doses.

#### Coenzyme Q10 Plus Fenofibrate Versus Fenofibrate Alone

Insufficient evidence was noted across all of the gradable clinical adverse events and organ toxicity outcomes for coenzyme Q10 plus fenofibrate versus fenofibrate alone, including withdrawal due to adverse events,58 elevated alanine transaminase,58 and elevated creatinine58 (Table 36). None of the included studies examined the gradable outcomes serious adverse events or bleeding. RCTs also reported abnormal electrocardiogram (ECG)58 and abnormal CK/CPK;58 zero events were observed. In another RCT, frequency of retinopathy was the same with coenzyme Q10 plus fenofibrates (5/20) versus fenofibrate alone (6/20).58 One RCT examined fasting blood glucose as a continuous outcome; no differences were observed.58

#### Coenzyme Q10 Plus ACE Inhibitors Versus ACE Inhibitors Alone

Insufficient evidence was noted across all of the gradable clinical adverse events and organ toxicity outcomes for coenzyme Q10 (33 mg three times daily) plus ACE inhibitors versus ACE inhibitors alone, including hepatoxocity (elevated alanine transaminase,54 aspartate aminotransferase54) and renal dysfunction (creatinine,54 blood urea nitrogen 54) (Table 37). None of the included studies examined the gradable outcomes serious adverse events, withdrawal due to adverse events or bleeding. One RCT also reported adverse events in general;54 zero events were observed.

Table 37 Strength of evidence for coenzyme Q10 with or without cardiovascular drugs—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Coenzyme Q10
Serious adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Withdrawal due to adverse events [2 studies] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive Study 1: 0 events Study 2: no significant differences; 6/22 events in intervention group versus 4/22 events in placebo group
Renal dysfunction (glomerular filtration rate [1 study]) | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Hepatotoxicity hepatoxicity (alanine transaminase, aspartate aminotransferase [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Fenofibrate
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 2 events total (not reported by group)
Renal dysfunction (creatinine [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No significant differences between groups, number of events not reported
Hepatotoxicity (alanine transaminase [study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
ACE inhibitors
Renal dysfunction (creatinine, blood urea nitrogen [n=1 study]) | | | | | | 0 events observed in 1 study
Hepatotoxicity (alanine transaminase, aspartate aminotransferase [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | 0 events observed in 1 study

Abbreviations: ACE = angiotensin-converting enzyme; NA = not applicable.

### Echinacea

A randomized open-label crossover trial in 12 healthy, non-smoking males with known CYP2C9 genotype reported zero total adverse events and withdrawal due to adverse events. The participants in this trial received a single dose of warfarin (25 mg/day) alone or after two weeks of pre-treatment with of 600 mg of Echinacea angustifolia roots plus 675 mg of E. purpurea root given four times a day59 Insufficient evidence was noted for the gradable outcome withdrawal due to adverse events (Table 38). Furthermore, this study did not report data on any of the other gradable outcomes (serious adverse events, bleeding, renal dysfunction or hepatotoxicity).59.

Table 38 Strength of evidence for warfarin with or without Echinacea—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed

Abbreviation: NA = not applicable.

### Garlic

Four RCTs examined garlic (4 to 10 g/day) plus warfarin, nitrates, or statins/aspirin versus warfarin, nitrates, or statins/aspirin alone.60–63 The included patients ranged from healthy, non-smoking males 61 to individuals with cardiac conditions.60,62,63 The majority of studies were parallel RCTs (one crossover RCT 61) of moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes.

#### Garlic Plus Warfarin Versus Warfarin Alone

Insufficient evidence was available for the gradable harm bleeding for garlic (4 to 10 g/day) plus warfarin versus warfarin alone (Table 39).60,61 In one study, bleeding was defined as hemorrhage, epistaxis, hemoptysis, hematuria, bloody stools, hemorrhage into organs, hemarthrosis, hematomas, or bruising.60 The other study simply indicated major bleeding episodes.61 None of the included RCTs examined the gradable outcomes serious adverse events, withdrawal due to adverse events, renal dysfunction or hepatotoxicity. One RCT examined fasting blood glucose and anemia;60 no statistically significant effects were observed.

Table 39 Strength of evidence for warfarin with or without garlic—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Warfarin
Bleeding [2 studies] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Aspirin
Renal dysfunction^*^ (creatinine, serum potassium [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed
Hepatotoxicity^*^ (aspartate aminotransferase, alanine transaminase, alkaline phosphatase [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed

Note:

* continuous data only (dichotomous data not available).

Abbreviation: NA = not applicable.

#### Garlic Plus Nitrates Versus Nitrates Alone

One RCT examined garlic (4 g/day) plus nitrates versus nitrates alone and did not report the results for any of the gradable harms.62 This RCT reported only one harm (fasting blood glucose as a continuous outcome) and found no statistically significant effects.62

#### Garlic Plus Statins/Aspirin Versus Statins/Aspirin Alone

Insufficient evidence was noted for the gradable outcomes renal dysfunction63 and hepatoxocity63 for garlic (4 mL/day) plus statins/aspirin versus statins/aspirin alone (Table 39). This RCT63 also reported harms data related to leukopenia and fasting blood glucose; no statistically significant effects were observed.

### Ginger

No evidence of gradable outcomes was identified for this supplement. Mild diarrhea in 1/12 subjects was found in one RCT after two days of supplementation with ginger (3.6 g/day) plus a single dose of warfarin.64

### Ginkgo Biloba

Seven RCTs examined Ginkgo biloba plus warfarin, aspirin, aspirin and/or pentoxiphylline, digoxin, statin/aspirin, cilostazol/clopidogrel or ticlopidine versus these cardiovascular medications alone.48,64–68,90 Two of these studies included a single dose of a cardiovascular medication so their results should be interpreted with caution.67,68 The included patients ranged from those at risk for peripheral artery disease66 or stroke,48 to healthy adults65,90 and all males.64,67,68 The majority of studies were crossover RCTs (two parallel RCTs 48,66) of moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes.

#### Ginkgo Biloba Plus Aspirin Versus Aspirin Alone

Insufficient evidence was noted across all of the gradable clinical adverse events and organ toxicity outcomes for G. biloba (240 mg/day,65, or 300 mg/day66) plus aspirin versus aspirin alone, including withdrawal due to adverse events,66 bleeding (nosebleeds and/or unusual bleeding),66 renal dysfunction,65 and hepatotoxicity65 (Table 40). None of the included studies examined the gradable outcome serious adverse events. No statistically significant differences were observed across the total adverse events (11/34 combination group versus 15/33 control group) and upset stomach (6/34 combination group versus 5/33 aspirin alone group) harms.66 One RCT reported anemia and white blood cell count using continuous data but found no significant differences between the groups taking G. biloba plus aspirin group and aspirin alone.65

Table 40 Strength of evidence for cardiovascular drugs with or without G. biloba—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Aspirin
Withdrawal due to adverse events [1 study] | Low | NA | Direct | Imprecise | Insufficient | Inconclusive No statistically significant differences, 3/34 intervention group versus 2/33 control group
Bleeding [1 study] | Low | NA | Direct | Imprecise | Insufficient | Inconclusive No statistically significant difference; 5/34 events intervention group versus 4/33 events control group
Renal dysfunction^*^ (1 study) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed
Hepatotoxicity^*^ (1 study) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed
Aspirin and/or pentoxiphylline
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Ticlopidine
Renal dysfunction (1 study) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Hepatotoxicity (1 study) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Warfarin
Serious adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Digoxin
Withdrawal due to adverse events[1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed

Note:

* continuous data only (dichotomous data not available).Renal dysfunction indication measures by creatinine, and or blood urea nitrogen levels; Hepatotoxicity measured by raised levels of aspartate aminotransaminase, and or alanine transaminase

Abbreviation: NA = not applicable.

#### Ginkgo Biloba Plus Aspirin and/or Pentoxiphylline Versus Aspirin and/or Pentoxiphylline Alone

Insufficient evidence was noted for the gradable harm withdrawal due to adverse events for G. biloba (40 mg every 6 hours)plus aspirin and/or pentoxiphylline versus aspirin and/or pentoxiphylline alone48 (Table 40). This RCT reported 4/33 gastrointestinal events in the G. biloba plus aspirin and/or pentoxiphylline group compared with 3/29 events in the control group,48 which was not statistically significant. There was no report of any of the gradable outcomes serious adverse events, bleeding, renal dysfunction or hepatotoxicity.

#### Ginkgo Biloba Plus Ticlopidine Versus Ticlopidine Alone

Insufficient evidence was noted for the gradable harms renal dysfunction (raised creatinine,68 or abnormal blood urea nitrogen68) and hepatotoxicity (elevated aspartate aminotransaminase,68 or elevated alkaline phosphatase68) for G. biloba (80 mg single dose) plus ticlopidine versus ticlopidine alone(Table 40). The included RCTs did not examine any of the gradable outcomes serious adverse events, withdrawal due to adverse events or bleeding. One RCT examined the effects of G. biloba plus ticlopidin versus ticlopidin alone on hypoglycemia, hyperglycemia, leukopenia, thrombocytopenia, anemia, and abnormal ECG; zero events were observed.68

#### Ginkgo Biloba Plus Warfarin Versus Warfarin Alone

Insufficient evidence was noted for the gradable harms serious adverse events and withdrawal due to adverse events for G. biloba (two tablets three times daily-each tablet with equivalent of 2 g of Ginkgo biloba leaf, 9.6 mg of ginkgo flavonglycosides, 2.4 mg of ginkgolides and bilobalide) plus warfarin versus warfarin alone (Table 40).64 This RCTs did not examine any of the other gradable harms, including bleeding, renal dysfunction, and hepatotoxicity. Furthermore, zero events were observed for constipation and no statistically significant differences were reported for diarrhea (0/12 combination group versus 1/12 control group).64

#### Ginkgo Biloba Plus Digoxin Versus Digoxin Alone

Insufficient evidence was noted for G. biloba (80 mg three times daily) plus digoxin versus digoxin alone related to withdrawal due to adverse events (Table 40).90 However, no data were available on the other gradable harms, including serious adverse events, bleeding, renal dysfunction, and hepatotoxicity. Furthermore, zero events were reported for adverse events and no statistically significant differences were noted for gastrointestinal adverse events (1/8 combination group versus 0/8 control group).90

#### Ginkgo Biloba Plus Cilostazol/Clopidogrel Versus Cilostazol/Clopidogrel Alone

Insufficient evidence was noted for Ginkgo biloba (120, and 240 mg/day) plus cilostazol/clopidogrel versus cilostazol/clopidogrel alone across all gradable outcomes, as none of these were reported.67 One RCT examined total adverse events; zero events were reported.67

### Ginseng

One parallel RCT examined the effects of 1.5 g/day Panax ginseng (aqueous extract containing0.5 grams three times daily) plus warfarin versus warfarin alone among patients who had experienced a stroke.69 Another parallel RCT examined the same comparison with 2 g/day American ginseng among healthy patients,70 while a crossover RCT examined the same comparison but with 3 g/day Korean ginseng among healthy non-smoking males.71 All three RCTs were of moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes. Insufficient evidence was noted across the gradable clinical adverse events, including withdrawal due to adverse events71 and bleeding (no description provided)69 (Table 41). None of the included RCTs examined the gradable outcome serious adverse events. Furthermore, insufficient evidence was noted for the organ toxicity outcomes (elevated creatinine,69 abnormal blood urea nitrogen,69 elevated aspartate aminotransaminase,69 and elevated alanine transaminase69), yet these were based on continuous data only (dichotomous data were not available). One RCT also examined prothrombin time, total adverse events, headache, dizziness, indigestion, INR above 3.5, diarrhea, and constipation;69 zero events were observed across all of these outcomes. Another RCT reported zero adverse events of clinical importance.70 One RCT examined the outcomes hematocrit and anemia using continuous data;69 no statistically significant differences were observed between intervention and control groups.

Table 41 Strength of evidence for warfarin with or without ginseng—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Bleeding | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Renal dysfunction^*^ (creatinine, blood urea nitrogen | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed
Hepatotoxicity^*^ (aspartate aminotransaminase, alanine transaminase | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed

Note:

* continuous data only (dichotomous data not available).

Abbreviation: NA = not applicable.

### Hawthorn

Tankanow and colleagues investigated the occurrence of harms with hawthorn and digoxin in eight healthy male volunteers in an open-label, randomized crossover trial of digoxin 0.25 mg/day for a 10-day period plus 900 mg/day of extract of hawthorn leaves with flowers standardized to 84.3 mg of oligomeric procyanidines for a 21 day period, versus digoxin alone for 10 days.72 This RCT did not report results for any of the gradable harms, including serious adverse events, withdrawal due to adverse events, bleeding, renal dysfunction, and hepatotoxicity. Furthermore, with sparse events, evidence was inconclusive for a difference between groups in flatulence, insomnia, headache, and dizziness.

### Magnesium

One parallel RCT examined the effects of 4.5 g/day oral magnesium plus hydrochlorthiazide versus hydrochlorthiazide alone,73 while another examined the same comparison with 15.78 mmol twice daily among hypertensive patients.74 In addition, one crossover RCT examined the effects of 365 mg/day oral magnesium plus various beta adrenergic antagonists versus beta adrenergic antagonists alone among hypertensive patients.42 All three RCTs had moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes.

#### Magnesium Plus Hydrochlorthiazide Versus Hydrochlorthiazide Alone

Insufficient evidence was noted across all of the gradable clinical adverse events and organ toxicity outcomes for magnesium plus hydrochlorthiazide versus hydrochlorthiazide alone, including withdrawal due to adverse events73 and renal dysfunction (elevated creatinine 74) (Table 42). None of the included RCTs examined the gradable outcomes serious adverse events, bleeding or hepatotoxicity. One RCT examining hydrochlorthiazide observed zero events across diarrhea, vomiting, nausea, adverse events, hypercalcemia, and fasting blood glucose harms.73 Furthermore, no statistically significant differences were observed for abnormal ECG (number of events not reported).73

Table 42 Strength of evidence for cardiovascular drugs with or without magnesium—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Hydrochlorthiazide
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Renal dysfunction (creatinine | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Beta-adrenergic antagonists
Serious adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Renal dysfunction^*^ (serum potassium) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences observed

Note:

* continuous data only (dichotomous data not available).

Abbreviation: NA = not applicable.

#### Magnesium Plus Beta Adrenergic Antagonists Versus Beta Adrenergic Antagonists Alone

Insufficient evidence was noted for magnesium (365 mg/day) plus beta adrenergic antagonists versus beta adrenergic antagonists alone for the gradable harms serious adverse events,42 withdrawal due to adverse events,42 and renal dysfunction (abnormal serum potassium42) (Table 42). None of the studies reported the gradable outcomes bleeding or hepatotoxicity.

### Niacin (Not More Than 250 mg)

Harms were investigated among 20 patients with hyperlipoproteinemia in an open-label, randomized crossover trial of niacin (250 mg/day) plus propranolol (20 mg/day) versus propranolol alone for 1 month.75 There was insufficient evidence for the gradable outcome withdrawals due to adverse events (Table 43).75 This study did not report gradable harms, such as serious adverse events, bleeding, renal dysfunction or hepatotoxicity. Furthermore, there were no statistically significant differences in nausea plus flushing (zero events) or hypotension plus asthenia (0/10 intervention group versus 1/10 control group).

Table 43 Strength of evidence for propranolol with or without niacin—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Withdrawal due to adverse events [n=1 study] | High | NA | Direct | Imprecise | Insufficient | Inconclusive No statistically significant differences; 0/10 intervention group versus 1/10 control group

Abbreviation: NA = not applicable.

### Omega-3 Fatty Acids/Fish Oils

Twenty-two studies (21 RCTs, and one retrospective cohort study) examined omega-3 fatty acids plus statins,36,37,40,53,92–97 aspirin,47,52,78,98,99,99 aspirin and clopidogrel,88 aspirin in combination with dipyridamole and calcium channel blockers,52 warfarin,47,55 rampril,77 or fenofibrate,56. The included participants ranged from elderly patients with CHD,82 to adults with diabetes 87 or stroke,49 to healthy males 39 or adults.36,93,95,99 The majority of studies were parallel RCTs, yet there were 7 crossover RCTs,36,37,93,95–97,99 and one retrospective cohort study.88 The majority were deemed as having moderate risk of bias, although two had low risk of bias 51,92 and one had high risk of bias.55 Meta-analysis was only possible for the statins; for all other cardiovascular medications, low event rates across all of the harms outcomes precluded pooling.

#### Omega-3 Fatty Acids/Fish Oils Plus Statins Versus Statins Alone

Eleven RCTs examined omega-3 fatty acids (2 to 9.2 g/day) plus statins versus statins alone.36,37,40,53,91–97 One RCT had low risk of bias,92 while the rest were of moderate risk of bias, including the seven RCTs included in the meta-analyses.36,37,40,91,93–96 Insufficient evidence was noted across all gradable outcomes, including serious adverse events meta-analysis (Figure 19), withdrawal due to adverse events meta-analysis (Figure 20), aminotransaminase meta-analysis (Figure 21), and alanine transaminase meta-analysis (Figure 22, Table 44). None of the included RCTs examined the gradable outcome bleeding.

Figure 19 Forest plot of serious adverse events with statins, with or without omega-3 fatty acids

Figure 19 is a forest plot that displays effect estimates for serious adverse events in subjects taking statins with or without omega 3 fatty acids. Three studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 3.64, lower bound 95% confidence interval 0.77, upper bound 95% confidence interval 17.22). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.05, p-value = 0.97).

Figure 20 Forest plot of withdrawal due to adverse events with statins, with or without omega-3 fatty acids

Figure 20 is a forest plot that displays effect estimates for withdrawal due to adverse events in subjects taking statins with or without omega-3 fatty acids. Seven studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 1.20, lower bound 95% confidence interval 0.62, upper bound 95% confidence interval 2.31). There was no heterogeneity (I2 = 0.0%, chi-squared = 1.98, p-value = 0.92).

Figure 21 Forest plot of aminotransaminase with statins, with or without omega-3 fatty acids

Figure 21 is a forest plot that displays effect estimates for aminotransferase in subjects taking statins with or without omega-3 fatty acids. Two studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 0.61, lower bound 95% confidence interval 0.30, upper bound 95% confidence interval 1.27). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.63, p-value = 0.43).

Figure 22 Forest plot of alanine transaminase with statins, with or without omega-3 fatty acids

Figure 22 is a forest plot that displays effect estimates for alanine transaminase in subjects taking statins with or without omega-3 fatty acids. Four studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 0.94, lower bound 95% confidence interval 0.46, upper bound 95% confidence interval 1.93). There was no heterogeneity (I2 = 0.0%, chi-squared = 2.32, p-value = 0.51).

Table 44 Strength of evidence for cardiovascular drugs with or without omega-3 fatty acids/fish oils—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Statins
Serious adverse events [meta-analysis including 3 studies] | Moderate | Consistent | Direct | Imprecise | Insufficient | Inconclusive No statistically significant differences; 0/10 intervention group versus 1/10 control group
Withdrawal due to adverse events [meta-analysis including 7 studies] | Moderate | Inconsistent | Direct | Imprecise | Insufficient | Inconclusive No significant differences; RR 3.6 (95% CI 0.8, 17.2)
Renal dysfunction^*^ (creatinine) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences; OR 1.2 (95% CI 0.6, 2.4)
Hepatotoxicity: aminotransaminase [meta-analysis including 2 studies] | Moderate | Consistent | Indirect surrogate | Imprecise | Insufficient | Inconclusive No significant differences
Hepatotoxicity: alanine transaminase [meta-analysis including 4 studies] | Moderate | Inconsistent | Indirect surrogate | Imprecise | Insufficient | Inconclusive No statistically significant differences; RR 0.61 (95% CI 0.30, 1.27)
Aspirin
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Bleeding [n=2 studies] | High | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences: Study 1: 0 events observed Study 2: 3/143 intervention group versus 2/148 control group
Aspirin + clopidogrel
Bleeding | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences: Major Bleeding: 1/182 intervention versus 0/182 control group Minor Bleeding: 4/182 intervention versus 7/182 control group
Aspirin + dipridamole + calcium channel blockers
Bleeding | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences: 3/43 intervention group versus 1/39 control group
Aspirin+ calcium channel blockers
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Bleeding [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Warfarin
Withdrawal due to adverse events | High | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Bleeding [2 studies] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences: Study 1: 0 events observed Study 2: 2/174 intervention group versus 2/145 control group
Ramipril and/or irbesartan
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | 0 events observed
Bleeding (Grade 3 erythrocyturia) | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences: 4/15 intervention group versus 1/15 control group
Renal dysfunction^*^ [glomerular filtration rate] | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | No statistically significant difference
Fenofibrate
Serious adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences; 3/84 intervention group versus 4/83 control group
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant differences 4/84 intervention group versus 4/83 control group
Renal dysfunction (creatinine) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive No significant differences 0/84 intervention group versus 1/83 control group

Note:

* continuous data only (dichotomous data not available).

Abbreviation: NA = not applicable.

Meta-analysis was also possible for total adverse events (5 studies; RR 0.94 [95 percent CI 0.78, 1.12] Figure 23), dyspepsia (2 studies; odds ratio [OR] 1.61 [95 percent CI 0.46, 5.55] Figure 24), headache (2 studies; OR 0.76 [95 percent CI 0.25, 2.30] Figure 25), constipation (2 studies; RR 0.94 [95 percent CI 0.63, 1.39] Figure 26), upper respiratory infection (2 studies; RR 1.33 [95 percent CI 0.34, 5.21] Figure 27), and CK/CPK (3; RR 1.50 [95 percent CI 0.43, 5.25] Figure 28); no statistically significant effects were observed. Results were consistently not statistically significant despite differences in low 36,93,95 versus moderate 37,40,94,96 CHD risk, and healthy patients 36,93,95 versus those with hyperlipidemia or dyslipidemia 37,40,94,96.

Figure 23 Forest plot of total adverse events with statins, with or without omega-3 fatty acids

Figure 23 is a forest plot that displays effect estimates for total adverse events in subjects taking statins with or without omega-3 fatty acids. Five studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 0.94, lower bound 95% confidence interval 0.78, upper bound 95% confidence interval 1.12). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.72, p-value = 0.95).

Figure 24 Forest plot of dyspepsia with statins with or without omega-3 fatty acids

Figure 24 is a forest plot that displays effect estimates for dyspepsia in subjects taking statins with or without omega-3 fatty acids. Two studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 1.61, lower bound 95% confidence interval 0.46, upper bound 95% confidence interval 5.65). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.14, p-value = 0.71).

Figure 25 Forest plot of headache with statins, with or without omega-3 fatty acids

Figure 25 is a forest plot that displays effect estimates for headache in subjects taking statins with or without omega-3 fatty acids. Two studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 0.76, lower bound 95% confidence interval 0.25, upper bound 95% confidence interval 2.30). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.04, p-value = 0.04).

Figure 26 Forest plot of constipation with statins, with or without omega-3 fatty acids

Figure 26 is a forest plot that displays effect estimates for constipation in subjects taking statins with or without omega-3 fatty acids. Two studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 0.94, lower bound 95% confidence interval 0.63, upper bound 95% confidence interval 1.39). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.09, p-value = 0.77).

Figure 27 Forest plot of upper respiratory infection with statins, with or without omega-3 fatty acids

Figure 27 is a forest plot that displays effect estimates for upper respiratory infection in subjects taking statins with or without omega-3 fatty acids. Two studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 1.33, lower bound 95% confidence interval 0.34, upper bound 95% confidence interval 5.21). There was no heterogeneity (I2 = 0.0%, chi-squared = 2.66, p-value = 0.10).

Figure 28 Forest plot of CK/CPK with statins, with or without omega-3 fatty acids

Figure 28 is a forest plot that displays effect estimates for creatinine kinase in subjects taking statins with or without omega-3 fatty acids. Three studies were pooled, yielding a statistically nonsignificant effect estimate (relative risk = 1.50, lower bound 95% confidence interval 0.43, upper bound 95% confidence interval 5.25). There was no heterogeneity (I2 = 0.0%, chi-squared = 0.63, p-value = 0.73).

We were unable to discern any effects of sex, ethnicity or age on the results, as these were not examined in the RCTs for which meta-analysis was deemed appropriate.

RCTs also reported many other harms outcomes for which no statistically significant differences were observed, such as diarrhea (3/122 intervention versus 3/132 control),40 flatulence (5/50 intervention versus 5/50 control),36 generalized edema (0/40 intervention versus 2/40 control),37 hyperglycemia (2/40 intervention versus 1/40 control),37 hypoglycemia (1/40 intervention versus 1/40 control),37 infection (4/122 intervention versus 1/132 control),40 myalgia (1/40 intervention versus 1/40 control),37 and sinusitis (0/40 intervention versus 2/40 control).37 The RCTs also examined harms outcomes as continuous variables, such as leukopenia,97 anemia,97 red blood cell count,97 hematocrit,97 glycosylated hemoglobin,94 and fasting blood glucose;37,40,44,53,76,91,92,94 and one RCT found a statistically significant elevated fasting blood glucose in the omega-3 fatty acids plus statins versus statins alone group.40

#### Omega-3 Fatty Acids/Fish Oils Plus Aspirin Versus Aspirin Alone

Six RCTs examined omega-3 fatty acids (4 to 10 mg/day) plus aspirin versus aspirin alone.47,52,78,98,99,99 Two of these RCTs were conducted among males only.52,98 Insufficient evidence was noted for all gradable outcomes, including withdrawal due to adverse events78 and bleeding 47,99(Table 44). Bleeding in one study was defined as those episodes leading to deviation from the protocol (major and minor bleeding episodes: major bleeding defined as bleeding necessitating operation or blood transfusion; minor bleeding defined as all other episodes).47 The second study reported bleeding episodes of any type.99.

None of the included RCTs examined the gradable outcomes serious adverse events, renal dysfunction or hepatotoxicity. No significant differences were observed across all harms, including constipation (1/12 intervention group versus 0/12 control group),99 diarrhea (0/12 intervention group versus1/12 control group),99 fishy taste (4/12 intervention group versus 0/12 control group),99 gastrointestinal adverse events (7/143 intervention group versus12/148 control group),47 flatulence (0/12 intervention group versus 1/12 control group),99 headache (1/12 intervention group versus 1/12 control group),99 and nausea (3/12 intervention group versus 3/12 control group).99 One RCT reported leukopenia as a continuous outcome, with no statistically significant differences observed.99

#### Omega-3 Fatty Acids/Fish Oils Plus Aspirin and Clopidogrel Versus Aspirin and Clopidogrel Alone

One retrospective cohort study examined the effect of fish oils (mean dose 3 g/day plus/minus 1.25 g/day) in combination with aspirin and clopidogrel in 182 elderly subjects with coronary artery disease.88 An age and gender matched control group of subjects taking aspirin and clopidogrel alone was selected. Major and minor bleeding episodes were noted after a follow-up of 33 months. Major bleeding was defined as a decrease in hemoglobin of more than two grams, intracerebral hemorrhage, or any bleeding episode that required hospitalization. Minor bleeding was defined as epistaxis, abnormal bruising, and gastrointestinal bleeding that did not require hospitalization or lead to a decrease in hemoglobin of more than 2 grams. No significant differences were found between intervention and control groups. Strength of evidence for bleeding was insufficient (Table 44).

#### Omega-3 Fatty Acids/Fish Oils Plus Aspirin, Dipyridamole, and Calcium Channel Blockers Versus Aspirin, Dipyridamole, and Calcium Channel Blockers

One RCT also examined the effects of omega-3 fatty acids (eicosapentaenoic 3.2 g/day) plus aspirin, dipyridamole, and calcium channel blockers versus aspirin, dipyridamole, and calcium channel blockers alone.52 Another RCT with a low risk of bias examined omega-3 fatty acids (3 g/day) plus aspirin and calcium channel blockers versus aspirin and calcium channel blockers alone.51 Insufficient evidence was noted for the gradable outcomes bleeding (described as bleeding complications)51,52 and withdrawal due to adverse events51 (Table 44). None of the included RCTs examined serious adverse events, renal dysfunction or hepatotoxicity. No statistically significant differences were observed regarding gastrointestinal events (7/43 intervention group versus 3/39 control group52).

#### Omega-3 Fatty Acids/Fish Oils Plus Warfarin Versus Warfarin Alone

Two RCTs examined the effects of omega-3 fatty acids (3–6 g/day) plus warfarin versus warfarin alone.47,55 Insufficient evidence was noted for the gradable outcomes bleeding 47,55 and withdrawals due to adverse events55 (Table 44). Bleeding in one study was defined as those episodes leading to deviation from the protocol (major and minor bleeding episodes: major bleeding defined as bleeding necessitating operation or blood transfusion; minor bleeding defined as all other episodes).47 The other study reported major bleeding (defined as bleeding episodes causing death or requiring hospitalization, vitamin K, or blood transfusion) and minor bleeding (defined as any bleeding episode that did not qualify as a major bleed but that required a change in warfarin dosage or referral).55 None of the included studies examined the gradable outcomes serious adverse events, renal dysfunction or hepatotoxicity. Furthermore, three patients with an unstable international normalized ratio withdrew. Data were not reported by treatment groups.55 One of the RCTs reported gastrointestinal events, which did not differ significantly between groups (9/174 intervention versus 0/145 control).47

#### Omega-3 Fatty Acids/Fish Oils Plus Ramipril and/or Irbesartan Versus Ramipril and/or Irbesartan Alone

One RCT with a moderate risk of bias examined the effects of fish or marine oils (3 g/day)plus ramipril among patients at low risk of CHD.77 Insufficient evidence was noted for the gradable outcomes withdrawal due to adverse events, bleeding (erythrocyturia grade 3), and renal dysfunction (glomerular filtration rate) (Table 44). This RCT did not report the results for other gradable harms, such as serious adverse events and hepatotoxicity. Furthermore, zero events were observed for hypercalcemia.

#### Omega-3 Fatty Acids/Fish Oils Plus Fenofibrate Versus Fenofibrate Alone

One RCT with a moderate risk of bias examined the effects of omega-3 fatty acids (4 g/day)plus fenofibrate versus corn oil plus fenofibrate among patients with low CHD risk.56 Insufficient evidence was noted for the gradable harms serious adverse events, withdrawal due to adverse events, and renal dysfunction (elevated creatinine) (Table 44). This RCT did not report results for the gradable harms bleeding or hepatotoxicity. Furthermore, no statistically significant differences were observed for constipation (1/84 intervention group versus 5/83 control group), diarrhea (4/84 intervention group versus 5/83 control group), flatulence (1/84 intervention group versus 3/83 control group), gastrointestinal adverse events (7/84 intervention group versus 5/83 control group) and nausea (5/84 intervention group versus 3/83 control group).

### Vitamin E

Ten RCTs examined vitamin E plus aspirin, statins, or furosemide versus these cardiovascular medications alone.39,46,49,81–84,86,87,100 The included participants ranged from the elderly with CHD,82 to those with diabetes,87 or stroke,49 to healthy females.39 The majority of studies were parallel RCTs (with two crossover RCTs 82,86) of moderate risk of bias. Meta-analysis was not possible due to the low event rate across all of the harms outcomes.

#### Vitamin E Plus Aspirin Versus Aspirin Alone

Three RCTs examined vitamin E plus aspirin versus aspirin alone.39,49,100 Insufficient evidence was noted for the gradable harms of bleeding (hemorrhagic events) after two years supplementation with vitamin E (400 IU/day) plus aspirin (325 mg/day) versus aspirin alone,49 and for withdrawals due to adverse events after 10 days of vitamin E supplementation (200 mg/day) plus low dose aspirin (80 mg/day) or aspirin alone100 (Table 45). None of the RCTs reported data related to the gradable harms serious adverse events, renal dysfunction or hepatotoxicity. No statistically significant differences were observed in the number of patients experiencing headache (28/121 intervention group versus 20/122 control group), gastrointestinal discomfort (14/121 intervention group versus 10/122 control group) or total adverse events (23/121 intervention group versus 24/122 control group) with 10 days of vitamin E supplementation (200 mg/day) plus low dose aspirin or aspirin alone.100 One RCT examined the occurrence of cancer, and no statistically significant differences were observed (716/9966 intervention group versus 722/9968 control group)in a large sample of women (aged 45 years or older) supplemented with vitamin E (600 IU/day) plus low dose aspirin (100 mg/day) or aspirin alone over the period of 10 years.39

Table 45 Strength of evidence for cardiovascular drugs with or without vitamin E—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Aspirin
Withdrawal due to adverse events [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant difference; 29/121 intervention group versus 19/122 control group
Bleeding [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No significant difference; 3/52 intervention group versus 3/48 control group
Nifedipine
Withdrawal due to adverse events [n=1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed
Renal dysfunction (creatinine [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Hepatotoxicity (alanine transaminase, aspartate aminotransferase [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Statins
Renal dysfunction (creatinine, blood urea nitrogen^*^ [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
Hepatotoxicity (alanine transaminase [2 studies], aspartate aminotransferase, alkaline phosphatase [1 study]) | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive 0 events observed
QT interval (continuous data) | Moderate | NA | Indirect Surrogate | Imprecise | Insufficient | Inconclusive No significant difference observed.

Note:

* continuous data only (dichotomous data not available).

Abbreviation: NA = not applicable.

#### Vitamin E Plus Nifedipine Versus Nifedipine Alone

One crossover RCT examined the effects of vitamin E (900 mg/day) plus nifedipine versus nifedipine alone over four months in 30 elderly and moderately obese participants with stable effort angina. Insufficient evidence was noted across all of the gradable harms, including withdrawal due to adverse events, renal dysfunction, and hepatotoxicity (zero events were observed).82 (Table 45) This RCT did not report on the gradable outcomes serious adverse events or bleeding. Furthermore, fasting plasma glucose was examined as a continuous outcome and no statistically significant difference was observed.82

#### Vitamin E Plus Furosemide Versus Furosemide Alone

One parallel RCT examined the effects of vitamin E (600 mg/day) plus furosemide versus furosemide alone over 4 weeks in 24 hypertensive participants, and did not report the results of any of the gradable outcomes. Fasting blood glucose was reported as a continuous outcome; no statistically significant effect was observed.81

#### Vitamin E Plus Statins Versus Statins Alone

Five RCTs examined the effects of vitamin E plus statins versus statins alone in hypercholesterolemic or hyperlipidemic,46,83,84,86 or diabetic participants.87 In one trial very low dose of vitamin E was administered (100 IU/day) over three months46 in contrast to two other trials using higher doses (750 IU/day,87 and 1000 IU/day84)over six months. Insufficient evidence was noted across the gradable harms: organ toxicity (elevated alanine transaminase) with 100 IU/day vitamin E plus statins46 or 1000 IU/day vitamin E plus statins over six months,84 aspartate aminotransferase (100 IU/day),46 abnormal alkaline phosphatase (100 IU/day),46 elevated creatinine (100 IU/day),46 abnormal blood urea nitrogen (100 IU/day)46), and QT intervals (measured as continuous variable) with 400 IU/day over eight weeks83 (Table 45). None of the RCTs reported data on the gradable harms serious adverse events, withdrawal due to adverse events or bleeding. Furthermore, glycosylated hemoglobin,87 leukopenia,46 and anemia,46 were examined as continuous outcomes and no statistically significant difference was observed. Change in urinary creatinine levels were not significantly different after 1 month supplementation with vitamin E (600 mg/day) plus statins versus 1 month statins treatment alone in one trial reporting this outcomes as a continuous variable.86

### Vitamin K

One parallel RCT (moderate risk of bias) examined the effects of vitamin K plus warfarin versus warfarin alone.41

#### Vitamin K Plus Warfarin Versus Warfarin Alone

One RCT examined the effects of vitamin K (phytomenadione150 μg/day) plus warfarin versus warfarin alone.41 Insufficient evidence was observed for the gradable harms of bleeding episodes (no further description provided) and withdrawals due to adverse events (Table 46). This RCT did not report the gradable harms serious adverse events, renal dysfunction or hepatotoxicity.

Table 46 Strength of evidence for anticoagulants with or without vitamin K—Harms outcomes

Cardiovascular Drugs(s)/Harm | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Phenprocoumon
Bleeding [1 study] | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No statistically significant differences for minor bleeding; Minor bleeding: 7/94 intervention group versus 10/95 control group Major bleeding: 2/94 intervention group versus 0/95 control group
Warfarin
Withdrawal due to adverse events | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive No statistically significant differences; 0/35 intervention group versus 2/33 control group
Bleeding | Moderate | NA | Direct | Imprecise | Insufficient | Inconclusive 0 events observed

Abbreviation: NA = not applicable.

### Key Question 3a Do the effect estimates of harms outcomes vary by age, ethnicity, gender, or health status?

A lack of evidence precluded exploration of heterogeneity in the effect estimates for harms across preidentified subgroups.

### Key Question 3b Is there a measurable interaction between cardiovascular drugs and dietary supplements for harms outcomes?

One RCT presented data that would allow examination of the interaction between vitamin E supplements and the cardiovascular medication aspirin. Participants in this study were 486 Norplant contraceptive implant receivers from five Asian centers. The main outcome of this study was vaginal bleeding, which is not discussed here (it was not an included outcome for the present review). This RCT found no significant difference in the rates of adverse events (headache, gastrointestinal discomfort, and withdrawal due to adverse events) among treatment regimes.100

### Main Points for Key Question 3—Harms Outcomes

In this section we examined the evidence on harms outcomes, comparing dietary supplement(s) coadministered with cardiovascular drug(s), to cardiovascular drug(s) alone.

- Fifty-seven RCTs and one retrospective cohort study contributed to the evidence.
- Overall, the studies were of moderate risk of bias across all harms, which ranged from minor (e.g., flatulence) to severe (e.g., leukopenia, hemorrhaging).
- No evidence was identified for the effects of ginger, red yeast rice extract, resveratrol, vitamin A, or vitamin D in combination with cardiovascular drugs on clinical harms.
- No evidence for the following prespecified clinical harms were found: neurologic adverse events (e.g., neuropathy, seizure), and allergic reactions (anaphylaxis, skin, transient acute airway disease).
- Sparse evidence precluded exploration of heterogeneity in the effect estimates for harms across preidentified subgroups.
- Meta-analysis was not possible due to the low event rate across all of the reported harms outcomes for all supplements examined except for omega-3 fatty acids.
- A majority of the studies reported no events or no statistically significant differences across all harms and all supplements, including Echinacea, garlic, G. biloba, ginseng, hawthorn, oral magnesium, niacin (not more than 250 mg/day), omega-3 fatty acids, vitamin E, and vitamin K.
- For all gradable outcomes for which evidence was found, the strength of evidence was graded insufficient because type II error could not be excluded due to low power of studies to examine harms.
- Four RCTs examined the effects of coenzyme Q10 plus statins, fenofibrate or ACE-inhibitors versus these medications alone.
- The evidence for benefit of coenzyme Q10 in reducing myalgia, based on two small pilot studies, was inconclusive. One RCT found superior effect of coenzyme Q10 plus stain versus vitamin E plus statins in reducing myalgia. Another RCT found no significant difference in posttreatment myopathic pain between coenzyme Q10 plus statin and statin alone groups.
- Insufficient evidence was noted for meta-analyses for serious adverse events, withdrawal due to adverse events, and hepatic toxicity (abnormal levels of aminotransaminase, and alanine transaminase) for omega-3 fatty acids plus statins versus statins alone.
- No statistically significant effects were observed for meta-analyses of omega-3 fatty acids/statins for the following outcomes: dyspepsia, headache, constipation, upper respiratory tract infection, and creatine kinase. None of the other omega-3 fatty acids RCTs found statistically significant results across all harms, except for one RCT that found a statistically significant elevated fasting blood glucose level. Six other RCTs did not observe a statistically significant difference for the blood glucose levels.

## Key Question 4 In adults taking cardiovascular drugs, what are the effects of concomitant use of specific dietary supplements (when compared to cardiovascular drugs alone or cardiovascular drugs and a different dietary supplement[s]) on pharmacokinetic outcomes (e.g., half-life [t1/2], area under the concentration curve [AUC]) of cardiovascular drugs of interest?

a. Do the effect estimates of pharmacokinetic outcomes vary by age, ethnicity, gender, or health status?
b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for pharmacokinetic outcomes?

### Overview

A total of 15 unique studies were screened in.36,59,61,64,68,70–72,90,93,95,101,142,145,147 Three studies were removed from evidence synthesis because the dose of the dietary supplement was not reported,145 a cardiovascular drug was used that is not marketed in the United States,142 and finally a poorer study design sequential, single group before-after Ginkgo biloba and ticlopidine interaction study did not add to the available randomized controlled trial (RCT) evidence.147 Thus, a total of 12 studies contributed evidence on exposure and pharmacokinetic outcomes (Table 47). Generally, these studies were open-label, crossover RCTs, of moderate risk of bias for outcomes of interest, and included between eight and 50 healthy volunteers (Table 48).

Table 47 Overview of included studies for pharmacokinetic outcomes—Key Question 4

Dietary Supplement | N of Studies Included for KQ 4 | Cardio-vascular Drug(s) | Study Design(s) | Participants | Study Region | Race/Ethnicity | Industry Funding or Potential for Conflict of Interest
Echinacea | 1^59^ | Warfarin | Crossover RCT | Healthy non-smoking males | Australia/New Zealand | Mixed – Caucasians and Asians/South Asians | Yes
Garlic | 2^61,101^ | Warfarin, simvastatin, and pravastatin | Crossover RCT | Healthy males | Australia/New Zealand and Europe | Mixed – Caucasians and Asians | No Yes101
Ginger | 1^64^ | Warfarin | Crossover RCT | Healthy non-smoking males | Australia/New Zealand | Mixed – Caucasians and Asians | No
Ginkgo biloba | 3^64,68,90^ | Ticlopidine, digoxin, and warfarin | Crossover RCT | Healthy adults | East Asia, North America and Australia/New Zealand | Asians, NR, and Mixed – Caucasians and Asians | Yes68 Unclear90 No64
Ginseng | 2^70,71^ | Warfarin | 1 crossover 1 parallel RCT | Healthy adults | Australia/New Zealand and North America | Mixed – Caucasians Asians and Hispanics | No
Hawthorn | 1^72^ | Digoxin | Crossover RCT | Healthy non-smoking adults | North America | NR | Unclear
omega-3 fatty acids | 3^36,93,95^ | Rosuvastatin, atorvastatin, and simvastatin | Crossover RCT | Healthy adults | North America | Mostly Caucasians, or mostly Hispanics | Yes

Abbreviations: NR = not reported; RCT = randomized controlled trial.

Table 48 Risk of bias and potential for conflict of interest—Key Question 4

Item | % of Total RCT Studies
All RCTs (N=12) | Yes | No | Unclear
Adequate generation of allocation sequence | 18 | 0 | 91
Allocation concealment | 0 | 0 | 109
Comparability of groups | 91 | 0 | 18
Purity of supplement | 82 | 18 | 9
Blinding of allocated intervention | 109 | 0 | 0
Adequately addressed missing data | 64 | 9 | 36
Freedom from potential for conflict of interest | 45 | 45 | 18
Crossover RCTs (N=11)
Suitability of crossover design for the study condition | 109 | 0 | 0
Free of carryover effect | 109 | 0 | 0
Appropriateness of statistical analysis for crossover design | 27 | 10 | 70
Comparability of groups between periods 1 and 2 | 0 | 0 | 109
Freedom from bias introduced by dropouts | 60 | 18 | 20

Abbreviations: N = total number; RCTs = randomized controlled trials.

Seven studies investigated cardiovascular drug kinetics following a single dose.59,61,64,68,71,90,101 In keeping with the United States Food and Drug Administration guidance,30 seven studies reported pharmacokinetic outcomes potentially indicating cardiovascular drug interactions such as the area under the concentration curve (AUC) and maximum concentration (C_max_)as geometric mean ratios (dietary supplement plus cardiovascular drug: drug alone) with corresponding 90 percent confidence intervals.36,59,61,64,68,71,93 Others reported data as posttreatment means or median changes from baseline or geometric mean ratio with 95 percent confidence intervals. Carryover effects in these crossover trials was not a major concern because all study designs incorporated adequate washout periods, that were well over five times the half-lives of the drugs and supplements under investigation. Detailed study characteristics and data are tabulated in Appendix C. Statistical analyses were undertaken to compare the combination of dietary supplement plus cardiovascular drug with the cardiovascular drug alone.

No evidence addressing Key Question 4 subquestions (a) or (b) was identified. No data were available on bioavailability and volume of distribution.

No studies were found examining pharmacokinetic interactions between coenzyme Q10, magnesium, niacin (not more than 250 mg/day), red yeast rice extract, resveratrol, vitamin A, vitamin D with or without calcium supplementation, vitamin E, or vitamin K, and a cardiovascular drug.

### Echinacea

A randomized open-label crossover trial investigated exposure and pharmacokinetic interactions between a mixture of 600 mg of Echinacea angustifolia root plus 675 mg of E. purpurea root given four times a day for a period of two weeks, with a single dose of 25 mg warfarin versus warfarin alone.59 Both S- and R-warfarin enantiomer specific pharmacokinetic parameters were reported, including AUC_∞_, C_max_, half-life, clearance and volume of distribution in 12 healthy males of known CYP2C9 and VKORC1 genotype. The 90 percent CIs for the geometric means of all parameters were all within the bioequivalence range of 80 percent to 125 percent. Although not considered to be clinically significant, a statistically significant decrease in S-warfarin AUC_∞,_ and increases in drug clearance and apparent volume of distribution were noted with coadministration of the supplement (GMRs [90 percent CIs]: 0.92[0.85, 0.99]; 1.09[1.01, 1.18]; and 1.09 [1.03, 1.18] respectively).59 Strength of evidence is summarized in Table 49.

Table 49 Strength of evidence for warfarin with or without Echinacea, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
AUC_∞_, C_max_, half-life, and clearance for S- and R-warfarin | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions

Abbreviations: AUC_∞_ = area under the concentration curve extrapolated to infinity; C_max_= maximum concentration; NA = not applicable.

### Garlic

An open-label, randomized, crossover trial of allicin (7.4 mg/day) pretreatment for two weeks plus a single dose of 25 mg warfarin versus a single dose of warfarin alone was conducted in 16 healthy males.61 Four participants were lost to followup or withdrew, so only 12 participants completed the study. GMRs of S- and R-warfarin AUC_∞_, C_max_, half-life and clearance for S- and R-warfarin were not statistically different; however, the 90 percent CIs went beyond the 0.8 to 1.25 clinical bioequivalence boundaries for C_max_ of both S- and R-warfarin (GMR [90 percent CI] S-warfarin 1.06 [0.77, 1.47]; R-warfarin 1.02 [0.8, 1.4]).61 Strength of evidence is summarized in Table 50.

Table 50 Strength of evidence for warfarin and statins with or without garlic, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Warfarin
AUC_∞_, half-life, and clearance for S- and R-warfarin | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions
C_max_ S- and R-warfarin | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Clinically significant interactions could not be ruled out in either direction
Simvastatin
AUC_0–24 h_ and half-life | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Clinically significant interactions could not be ruled out in either direction based on 95% CI of GMRs
Clearance, C_max_ | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive results because type II error could not be excluded
Pravastatin
AUC_0–24 h_ and half-life | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Clinically significant interactions could not be ruled out in either direction based on 95% CI of GMRs
Clearance, C_max_ | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive results because type II error could not be excluded

Abbreviations: AUC_∞_ = area under the concentration curve extrapolated to infinity; C_max_= maximum concentration; NA = not applicable.

A crossover randomized trial investigated changes in baseline statin pharmacokinetics following coadministation with 3600mg of allicin given twice daily. The study randomized 10 healthy adults to single doses of simvastatin 20 mg and pravastatin 20 mg with a crossover after 24 hours.101 Subsequently all patients were administered garlic tablet additionally continuing 12000mg of gamma glutamylcysteine and 3800mg of thiosulfinates for 21 days in the last 2 days randomized to single dose of one of the statins with a second crossover to the other. Hence, the investigation of change in statin pharmacokinetic with addition of garlic essentially originated in a nonrandomized before-after experimental study. Ninety-five percent geometric mean ratios of AUC_0–24 h_ and half-life of statins were reported which included but went beyond the FDA specified margins of bioequivalence based on 90 percent GMR. The difference in pre and postgarlic means in the outcomes of clearance, C_max_, and time to the maximum concentration (t_max_) were not statistically significant, however, the data were not analyzed GMR with 90 percent CIs.

### Ginger

Twelve healthy males participated in a study of ginger interaction with warfarin, in an open-label randomized crossover trial.64 A single dose of 25 mg warfarin was preceded and followed by either no supplement or ginger (3.6 g of ginger rhizome per day) for 7 days. Statistically significant decreases in the t_max_ were observed for both S- and R-warfarin enantiomers (GMR [90 percent CI] S-warfarin 0.79 [0.73, 0.85]; R-warfarin 0.79 [0.73, 0.85]); the clinical significance of these findings is unclear. No interactions were noted for AUC_∞_, C_max_, half-life, clearance and volume of distribution; the GMR 90 percent CIs were not statistically significant, and were within the bioequivalence boundaries of 80 percent to 125 percent (Table 51).64

Table 51 Strength of evidence for ginger plus warfarin versus warfarin alone, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
AUC_∞_, C_max_, half-life, and clearance for S- and R-warfarin | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions

Abbreviations: AUC_∞_ = area under the concentration curve extrapolated to infinity; C_max_= maximum concentration; NA = not applicable.

### Ginkgo Biloba

Three studies examined pharmacokinetic interaction of Ginkgo biloba and specific cardiovascular drugs.64,68,90 All three studies were randomized crossover trials in healthy adults.

In a study of 24 young healthy Korean males, single doses of ticlopidine (250 mg) were administered with or without G. biloba (80 mg).68 GMRs of AUC_∞_ and C_max_ of ticlopidine were not statistically different from unity, and were clinically nonsignificant (Appendix C). Ticlopidine mean half-life and median t_max_ were not significantly affected by coadministration with G. biloba.68

In eight healthy adults, digoxin mean AUC_∞_, C_max_, clearance, elimination rate constant, t_max_ and half-life were not statistically different with 7 day treatment with G. biloba (240 mg/day) plus a single dose of 0.5 mg of oral digoxin on the last day, versus a single dose of 0.5 mg digoxin alone.90 GMRs were not reported, or could be calculated in the absence of individual patient data; therefore, we could not rule out clinical interaction based on the predefined GMR margins of bioequivalence.90

In 12 healthy male participants, no statistically or clinically significant differences were noted in geometric mean ratios of AUC_∞_, C_max_, half-life, clearance and volume of distribution of warfarin when administered as a 25 mg single dose with 7 day pre-treatment with Ginkgo biloba (12 g/day) or alone.64 However, there was significant reduction in tmax of both S- and R-warfarin enantiomers (GMR [90 percent CI]: 0.68 [0.63, 0.73]; 0.72 [0.67, 0.77], respectively). Based on the available data by group, we estimated that this decrease amounted to approximately 33 percent and 23 percent decreases in t_max_ arithmetic means for S- and R-warfarin enantiomers respectively.64

Strength of evidence is summarized in Table 52.

Table 52 Summary and strength of evidence for ticlopidine, digoxin and warfarin with or without G. biloba, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Ticlopidine
AUC_∞_, Half-life and C_max_ | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions
Clearance | - | - | - | - | Insufficient | Data not reported
Digoxin
AUC_∞_, C_max_, half-life, and clearance | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive results because type II error could not be excluded
Warfarin
AUC_∞_, C_max_, half-life, and clearance for S- and R-warfarin | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions

Abbreviations: AUC_∞_ = area under the concentration curve extrapolated to infinity; C_max_= maximum concentration; NA = not applicable.

### Ginseng

Interactions between American ginseng (Panax quinquefolius, 2 g/day from weeks 2 to 4)and warfarin (5 mg/day for 3 consecutive days of weeks 1 and 4) given over 4 weeks were investigated in a parallel randomized double blind placebo controlled trial in 20 healthy volunteers.70 Compared with controls administered warfarin alone, a statistically significant reduction in the warfarin AUC was noted when ginseng was coadministered (between group difference in median change between week 4 and week 1-0.64 μg/mL per day [95 percent CI, μ1.25, μ0.13]).70 The clinical significance of this finding is unclear because analysis was not based on geometric mean ratios.

A second open-label randomized crossover trial in 12 healthy males of a single dose of 25 mg warfarin coadministered with a 7 day pretreatment with Korean ginseng (2 capsules 3 times a day, each capsule containing 0.5 g Panax ginseng root and 8.93 mg ginsenosides) or alone, found clinically interpretable results.71 The geometric mean ratios of S- and R-warfarin AUC_∞_, C_max_, half-life, clearance and volume of distribution were neither statistically nor clinically different, indicating no interaction. The GMR for t_max_ of both S- and R-warfarins showed statistically nonsignificant results, but the lower and upper bounds of the 90 percent CI crossed the predefined bioequivalence boundaries (S- and R-warfarin tmax GMR [90 percent CI]: 1.20 [0.77, 1.62]; 1.11 [0.78, 1.44], respectively).71

Strength of evidence is summarized in Table 53.

Table 53 Summary and strength of evidence for warfarin with or without ginseng, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
C_max_, half-life, and clearance for S- and R-warfarin | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions for Korean and American ginseng
AUC_∞_ | Moderate | Inconsistent | Indirect surrogate | Imprecise | Insufficient | The evidence of American ginseng and warfarin interaction is unclear because statistically significant reduction in AUC of warfarin was noted, but clinical significance is unclear.

Abbreviations: AUC_ss_ = steady state area under the concentration curve; NA = not applicable.

### Hawthorn

Pharmacokinetic interactions between hawthorn(Craetagus oxycantha) and digoxin were investigated in eight healthy male volunteers in an open-label, randomized crossover trial of digoxin 0.25 mg/day for a 10 day period plus 900 mg/day of extract of hawthorn leaves with flowers standardized to 84.3 mg of oligomeric procyanidins for a 21 day period, versus digoxin alone for ten days.72 Using a paired analysis, the differences in means of AUC_∞_, C_max_, t_max_, half-life, and clearance did not reach statistical significance.

Strength of evidence is summarized in Table 54.

Table 54 Strength of evidence for digoxin with or without hawthorn, for Key Question 4

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Digoxin AUC_∞_, C_max_, half-life, and clearance | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive results because type II error could not be excluded

Abbreviations: AUC_ss_ = steady state area under the concentration curve; NA = not applicable.

### Omega-3 Fatty Acids/Fish Oils

Three open-label randomized crossover studies in 24 to 50 healthy adult volunteers investigated interactions between omega-3 fatty acids and various statins.36,93,95 Each study compared statin (rosuvastatin 40 mg/day, atorvastatin 80 mg/day, or simvastatin 80 mg/day) coadministered with 4 g/day of omega-3 fatty acids, with statin alone over a 14 day period. Due to the differences in first pass metabolism among various statins,166 we did not conduct meta-analysis of outcomes data. No statistically or clinically significant differences were noted for steady state AUC and C_max_ GMRs for rosuvastatin, atorvastatin, 2-hydroxyatorvastatin, and 4-hydroxyatorvastatin. No statistically significant changes were observed in steady state β-hydroxysimvastatin arithmetic means of AUC, C_max_, t_max_, clearance and half-life.36,93,95

Strength of evidence is summarized in Table 55.

Table 55 Strength of evidence for statins with or without omega-3 fatty acids/fish oil—Harms outcomes

Gradable Outcomes | Risk of Bias | Consistency | Directness | Precision | Grade | Conclusion Treatment Effect
Rosuvastatin, atorvastatin, 2- hydroxyatorvastatin and 4-hydroxyatorvastatin AUC_ss_, C_max_ | Moderate | NA | Indirect surrogate | Precise | Low | No clinically significant interactions
Half-life, and clearance of rosuvastatin, atorvastatin, 2-hydroxyatorvastatin and 4-hydroxyatorvastatin Beta-hydroxysimvastatin AUC_ss_, C_max_, half-life, and clearance | Moderate | NA | Indirect surrogate | Imprecise | Insufficient | Inconclusive results because type II error could not be excluded

Abbreviations: AUC_ss_ = steady state area under the concentration curve; C_max_= maximum concentration; NA = not applicable.

Applicability. Evidence of interaction affecting pharmacokinetic outcomes may not translate into altered clinical effectiveness or harms. Evidence originating in healthy young adults is not representative of older patients taking cardiovascular drugs. Metabolism of cardiovascular drugs may differ between the populations studied in these trials and CHD patients.

### Key Question 4a Do the effect estimates of pharmacokinetic outcomes vary by age, ethnicity, gender, or health status?

A paucity of evidence for supplement-drug combinations precluded exploration of heterogeneity in terms of preidentified subgroups such as age and gender.

### Key Question 4b Is there a measurable interaction between cardiovascular drugs and dietary supplements for pharmacokinetic outcomes?

Statistical interaction data were not reported in any pharmacokinetic study.

### Main Points for Key Question 4—Pharmacokinetic Outcomes

In this section we examined the evidence on pharmacokinetics of cardiovascular drugs when coadministered with or without a dietary supplement. Clinical significance of interaction was evaluated using the FDA guidance. According to the guidance, a statistically significant interaction does not determine clinical significance of interactions unless the 90 percent confidence intervals of the geometric mean ratios fall outside of the defined no effect range of 0.80 to 1.25.

- Twelve randomized controlled trials contributed evidence on pharmacokinetic outcomes.
- All trials were conducted in small numbers of healthy participants.
- No studies were found examining pharmacokinetic interactions between coenzyme Q10, magnesium, niacin (not more than 250 mg/day), red yeast rice extract, resveratrol, vitamin A, vitamin D with or without calcium supplementation, vitamin E, or vitamin K, and a cardiovascular drug.
- No clinically significant interactions were noted when Echinacea, ginger, or Ginkgo biloba were coadministered with warfarin, and when Ginkgo biloba was coadministered with ticlopidine. The strength of evidence for these finding was graded as low because evidence was limited to single pharmacokinetic studies with moderate risk of bias. Available evidence was insufficient, precluding meaningful conclusions about interactions between garlic and warfarin, garlic and statins, Ginkgo biloba and digoxin, omega-3 fatty acids and simvastatin, and hawthorn and digoxin. Interactions between ginseng and warfarin, and omega-3 fatty acids and rosuvastatin or atorvastatin were unclear; for some of the pharmacokinetic outcomes there was low strength of evidence suggesting no clinically relevant interactions, and insufficient evidence for others.
- A paucity of studies of supplement-drug combinations for which data were available precluded exploration of heterogeneity in terms of preidentified subgroups such as age and gender. Statistical interaction was not investigated in any pharmacokinetic study.