# References

1 Lloyd-Jones D, Adams RJ, Brown TM, et al. Heart disease and stroke statistics--2010 update: a report from the American Heart Association. Circ Cardiovasc Qual Outcomes. Feb. 23. 2010;121(7):e46-e215. [pmid: 20019324].
2 Brautbar A, Ballantyne CM. Pharmacological strategies for lowering LDL cholesterol: statins and beyond. Nat Rev Cardiol. May. 2011;8(5):253-65. [pmid: 21321561].
3 Mills EJ, Rachlis B, Wu P, et al. Primary prevention of cardiovascular mortality and events with statin treatments: a network meta-analysis involving more than 65,000 patients. J Am Coll Cardiol. Nov. 25. 2008;52(22):1769-81. [pmid: 19022156].
4 Choudhry NK, Fischer MA, Avorn J, et al. The implications of therapeutic complexity on adherence to cardiovascular medications. Arch Intern Med. May. 9. 2011;171(9):814-22. [pmid: 21555659].
5 What is complementary and alternative medicine?. National Center for Complementary and Alternative Medicine. http://nccam.nih.gov/health/whatiscam/. Accessed June 20, 2011.
6 Miller KL, Liebowitz RS, Newby LK. Complementary and alternative medicine in cardiovascular disease: A review of biologically based approaches. Am Heart J. 2004;147(3):401-11. [pmid: 14999187].
7 Yeh GY, Davis RB, Phillips RS. Use of complementary therapies in patients with cardiovascular disease. Am J Cardiol. Sep. 1. 2006;98(5):673-80. [pmid: 16923460].
8 Nahin RL, Barnes PM, Stussman BJ, et al. Costs of complementary and alternative medicine (CAM) and frequency of visits to CAM practitioners: United States, 2007. Natl Health Stat Report. Jul. 30. 2009;(18):1-14. [pmid: 19771719].
9 Zick SM, Blume A, Aaronson KD. The prevalence and pattern of complementary and alternative supplement use in individuals with chronic heart failure. J Card Fail. Oct. 2005;11(8):586-9. [pmid: 16230260].
10 Tachjian A, Maria V, Jahangir A. Use of herbal products and potential interactions in patients with cardiovascular diseases. [Review] [88 refs]. J Am Coll Cardiol. Feb. 9. 2010;55(6):515-25. [pmid: 20152556].
11 Mashour NH, Lin GI, Frishman WH. Herbal medicine for the treatment of cardiovascular disease: clinical considerations. [Review] [125 refs]. Arch Intern Med. Nov. 9. 1998;158(20):2225-34. [pmid: 9818802].
12 Maraldi C, Lattanzio F, Onder G, et al. Variability in the prescription of cardiovascular medications in older patients: correlates and potential explanations. Drugs Aging. Dec. Suppl 1. 2009;26:41-51. [pmid: 20136168].
13 Garner JB. Problems of nonadherence in cardiology and proposals to improve outcomes. Am J Cardiol. May. 15. 2010;105(10):1495-501. [pmid: 20451702].
14 Ulbricht C, Chao W, Costa D, et al. Clinical evidence of herb-drug interactions: a systematic review by the natural standard research collaboration. [Review] [1359 refs]. Curr Drug Metab. Dec. 2008;9(10):1063-120. [pmid: 19075623].
15 Voelker R. Cardiac patients' herbal supplement use deserves more careful investigation. JAMA. Mar. 3. 2010;303(9):824. [pmid: 20197523].
16 Qato DM, Alexander GC, Conti RM, et al. Use of prescription and over-the-counter medications and dietary supplements among older adults in the United States. JAMA. Dec. 24. 2008;300(24):2867-78. [pmid: 19109115].
17 Agency for Healthcare Research and Quality. Methods reference guide for effectiveness and comparative effectiveness reviews. [Version 1.0.]. Draft posted Oct. 2007http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Accessed July 14, 2011.
18 Pharand C, Ackman ML, Jackevicius CA, et al. Use of OTC and herbal products in patients with cardiovascular disease. Ann Pharmacother. Jun. 2003;37(6):899-904. [pmid: 12773082].
19 Gohar F, Greenfield SM, Gareth BD, et al. Self-care and adherence to medication: A survey in the hypertension outpatient clinic. BMC Complementary and Alternative Medicine. 2008;8(1). Article Number: 4 Date of Publication: 08 Feb 2008 2008;(1).
20 Balluz LS, Kieszak SM, Philen RM, et al. Vitamin and mineral supplement use in the United States: Results from the third national health and nutrition examination survey. Arch Fam Med. 2000;9(3):258-62. [pmid: 10728113].
21 Schellhorn B, Doring A, Stieber J. Use of vitamin and mineral supplements: Results from the survey 1994/95 of the WHO MONICA Project Augsburg. [German]. Z Ernahrungswiss. 1998;37(2):198-206. [pmid: 9698648].
22 Nahin RL, Pecha M, Welmerink DB, et al. Concomitant use of prescription drugs and dietary supplements in ambulatory elderly people. J Am Geriatr Soc. Jul. 2009;57(7):1197-205. [pmid: 19515113].
23 Barnes PM, Bloom B, Nahin RL. Complementary and alternative medicine use among adults and children: United States, 2007. Natl Health Stat Report. Dec. 10. 2008;(12):1-23. [pmid: 19361005].
24 Grundy SM, Cleeman JI, Merz CN, et al. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circ Cardiovasc Qual Outcomes. Jul. 13. 2004;110(2):227-39. [pmid: 15249516].
25 Santaguida P, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies: Manual for use of the McHarm. http://hiru.mcmaster.ca/epc/mcharm.pdf. Accessed December 22, 2010.
26 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
27 U.S. Food and Drug Administration. What is a Serious Adverse Event?. http://www.fda.gov/safety/medwatch/howtoreport/ucm053087.htm. Accessed August 7, 2011.
28 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
29 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. Oct. 2006;59(10):1040-8. [pmid: 16980143].
30 Approved drug products with therapeutic equivalence evaluations. Rockville (MD). U.S. Department of Health and Human Services. Food and Drug Administration. Center for Drug Evaluation and Research. Office of Pharmaceutical Science. Office of Generic Drugs. 2011. 31st ed.
31 Elbourne DR, Altman DG, Higgins JP, et al. Meta-analyses involving cross-over trials: methodological issues. Int J Epidemiol. Feb. 2002;31(1):140-9. [pmid: 11914310].
32 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the effective health care program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. [pmid: 21477993].
33 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
34 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. Jan. 15. 2007;26(1):53-77. [pmid: 16596572].
35 Takkouche B, Etminan M, Caamano F, et al. Interaction between aspirin and ACE Inhibitors: resolving discrepancies using a meta-analysis. Drug Saf. 2002;25(5):373-8. [pmid: 12020174].
36 Di Spirito M, Morelli G, Doyle RT, et al. Effect of omega-3-acid ethyl esters on steady-state plasma pharmacokinetics of atorvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2939-45. [pmid: 19006470].
37 Maki KC, McKenney JM, Reeves MS, et al. Effects of adding prescription omega-3 acid ethyl esters to simvastatin (20 mg/day) on lipids and lipoprotein particles in men and women with mixed dyslipidemia. [Erratum appears in Am J Cardiol. 2008 Nov 15;102(10):1425]. Am J Cardiol. Aug. 15. 2008;102(4):429-33. [pmid: 18678300].
38 Young JM, Florkowski CM, Molyneux SL, et al. Effect of coenzyme Q(10) supplementation on simvastatin-induced myalgia. Am J Cardiol. Nov. 1. 2007;100(9):1400-3. [pmid: 17950797].
39 Glynn RJ, Ridker PM, Goldhaber SZ, et al. Effects of random allocation to vitamin E supplementation on the occurrence of venous thromboembolism: report from the Women's Health Study. Circ Cardiovasc Qual Outcomes. Sep. 25. 2007;116(13):1497-503. [pmid: 17846285].
40 Davidson MH, Stein EA, Bays HE, et al. Efficacy and tolerability of adding prescription omega-3 fatty acids 4 g/d to simvastatin 40 mg/d in hypertriglyceridemic patients: an 8-week, randomized, double-blind, placebo-controlled study. Clin Ther. Jul. 2007;29(7):1354-67. [pmid: 17825687].
41 Sconce E, Avery P, Wynne H, et al. Vitamin K supplementation can improve stability of anticoagulation for patients with unexplained variability in response to warfarin. Blood. Mar. 15. 2007;109(6):2419-23. [pmid: 17110451].
42 Wirell MP, Wester PO, Stegmayr BG. Nutritional dose of magnesium in hypertensive patients on beta blockers lowers systolic blood pressure: a double-blind, cross-over study. J Intern Med. Aug. 1994;236(2):189-95. [pmid: 7913949].
43 Miyamoto S, Kawano H, Takazoe K, et al. Vitamin E improves fibrinolytic activity in patients with coronary spastic angina. Thromb Res. 2004;113(6):345-51. [pmid: 15226088].
44 Chan DC, Watts GF, Mori TA, et al. Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. Eur J Clin Invest. Jun. 2002;32(6):429-36. [pmid: 12059988].
45 Motoyama T, Kawano H, Kugiyama K, et al. Vitamin E administration improves impairment of endothelium-dependent vasodilation in patients with coronary spastic angina. J Am Coll Cardiol. Nov. 15. 1998;32(6):1672-9. [pmid: 9822095].
46 Napoli C, Leccese M, Palumbo G, et al. Effects of vitamin E and HMG-CoA reductase inhibition on cholesteryl ester transfer protein and lecithin-cholesterol acyltransferase in hypercholesterolemia. Coron Artery Dis. 1998;9(5):257-64. [pmid: 9710685].
47 Eritsland J, Arnesen H, Gr⊘nseth K, et al. Effect of dietary supplementation with n-3 fatty acids on coronary artery bypass graft patency. Am J Cardiol. Jan. 1. 1996;77(1):31-6. [pmid: 8540453].
48 Garg RK, Nag D, Agrawal A. A double blind placebo controlled trial of ginkgo biloba extract in acute cerebral ischaemia. J Assoc Physicians India. Nov. 1995;43(11):760-3. [pmid: 8773035].
49 Steiner M, Glantz M, Lekos A. Vitamin E plus aspirin compared with aspirin alone in patients with transient ischemic attacks. Am J Clin Nutr. Dec. 1995;62(6 Suppl):1381S-4S. [pmid: 7495235].
50 Yamamoto H, Yoshimura H, Noma M, et al. Improvement of coronary vasomotion with eicosapentaenoic acid does not inhibit acetylcholine-induced coronary vasospasm in patients with variant angina. [Erratum appears in Jpn Circ J 1995 Nov;59(11):773–4]. Jpn Circ J. Sep. 1995;59(9):608-16. [pmid: 7500544].
51 Kaul U, Sanghvi S, Bahl VK, et al. Fish oil supplements for prevention of restenosis after coronary angioplasty. Int J Cardiol. Apr. 1992;35(1):87-93. [pmid: 1563884].
52 Dehmer GJ, Popma JJ, van den Berg EK, et al. Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids. N Engl J Med. Sep. 22. 1988;319(12):733-40. [pmid: 2842680].
53 Liu M, Wallmon A, Wallin R, et al. Effects of stable fish oil and simvastatin on plasma lipoproteins in patients with hyperlipidemia. Nutr Res. 2003;23(8):1027-34.
54 Watson PS, Scalia GM, Galbraith A, et al. Lack of effect of coenzyme Q on left ventricular function in patients with congestive heart failure. J Am Coll Cardiol. 1999;33(6):1549-52. [pmid: 10334422].
55 Bender NK, Kraynak MA, Chiquette E, et al. Effects of marine fish oils on the anticoagulation status of patients receiving chronic warfarin therapy. J Thromb Thrombolysis. 1998;5(3):257-61. [pmid: 10767122].
56 Roth EM, Bays HE, Forker AD, et al. Prescription omega-3 fatty acid as an adjunct to fenofibrate therapy in hypertriglyceridemic subjects. J Cardiovasc Pharmacol. Sep. 2009;54(3):196-203. [pmid: 19597368].
57 Mabuchi H, Nohara A, Kobayashi J, et al. Effects of CoQ10 supplementation on plasma lipoprotein lipid, CoQ10 and liver and muscle enzyme levels in hypercholesterolemic patients treated with atorvastatin: a randomized double-blind study. Atherosclerosis. Dec. 2007;195(2):e182-e189. [pmid: 17681347].
58 Playford DA, Watts GF, Croft KD, et al. Combined effect of coenzyme Q10 and fenofibrate on forearm microcirculatory function in type 2 diabetes. Atherosclerosis. May. 2003;168(1):169-79. [pmid: 12732401].
59 Abdul MI, Jiang X, Williams KM, et al. Pharmacokinetic and pharmacodynamic interactions of echinacea and policosanol with warfarin in healthy subjects. Br J Clin Pharmacol. May. 2010;69(5):508-15. [pmid: 20573086].
60 Macan H, Uykimpang R, Alconcel M, et al. Aged garlic extract may be safe for patients on warfarin therapy. J Nutr. Mar. 2006;136(3 Suppl):793S-5S. [pmid: 16484565].
61 Mohammed Abdul MI, Jiang X, Williams KM, et al. Pharmacodynamic interaction of warfarin with cranberry but not with garlic in healthy subjects. Br J Pharmacol. Aug. 2008;154(8):1691-700. [pmid: 18516070].
62 Bordia A, Verma SK, Srivastava KC. Effect of garlic (Allium sativum) on blood lipids, blood sugar, fibrinogen and fibrinolytic activity in patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. Apr. 1998;58(4):257-63. [pmid: 9654398].
63 Budoff MJ, Takasu J, Flores FR, et al. Inhibiting progression of coronary calcification using Aged Garlic Extract in patients receiving statin therapy: a preliminary study. Prev Med. Nov. 2004;39(5):985-91. [pmid: 15475033].
64 Jiang X, Williams KM, Liauw WS, et al. Effect of ginkgo and ginger on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects. Br J Clin Pharmacol. Apr. 2005;59(4):425-32. [pmid: 15801937].
65 Wolf HR. Does Ginkgo biloba special extract EGb 761 provide additional effects on coagulation and bleeding when added to acetylsalicylic acid 500 mg daily?. Drugs in R &D. 2006;7(3):163-72. [pmid: 16752942].
66 Gardner CD, Zehnder JL, Rigby AJ, et al. Effect of Ginkgo biloba (EGb 761) and aspirin on platelet aggregation and platelet function analysis among older adults at risk of cardiovascular disease: a randomized clinical trial. Blood Coagul Fibrinolysis. Dec. 2007;18(8):787-93. [pmid: 17982321].
67 Aruna D, Naidu MU. Pharmacodynamic interaction studies of Ginkgo biloba with cilostazol and clopidogrel in healthy human subjects. Br J Clin Pharmacol. Mar. 2007;63(3):333-8. [pmid: 17010102].
68 Kim BH, Kim KP, Lim KS, et al. Influence of Ginkgo biloba extract on the pharmacodynamic effects and pharmacokinetic properties of ticlopidine: an open-label, randomized, two-period, two-treatment, two-sequence, single-dose crossover study in healthy Korean male volunteers. Clin Ther. Feb. 2010;32(2):380-90. [pmid: 20206795].
69 Lee SH, Ahn YM, Ahn SY, et al. Interaction between warfarin and Panax ginseng in ischemic stroke patients. J Altern Complement Med. Jul. 2008;14(6):715-21. [pmid: 18637764].
70 Yuan CS, Wei G, Dey L, et al. Brief communication: American ginseng reduces warfarin's effect in healthy patients: a randomized, controlled Trial. Ann Intern Med. Jul. 6. 2004;141(1):23-7. [pmid: 15238367].
71 Jiang X, Williams KM, Liauw WS, et al. Effect of St John's wort and ginseng on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects. [Erratum appears in Br J Clin Pharmacol. 2004 Jul;58(1):102]. Br J Clin Pharmacol. May. 2004;57(5):592-9. [pmid: 15089812].
72 Tankanow R, Tamer HR, Streetman DS, et al. Interaction study between digoxin and a preparation of hawthorn (Crataegus oxyacantha). J Clin Pharmacol. Jun. 2003;43(6):637-42. [pmid: 12817526].
73 Paolisso G, Di Maro G, Cozzolino D, et al. Chronic magnesium administration enhances oxidative glucose metabolism in thiazide treated hypertensive patients. Am J Hypertens. Oct. 1992;5(10):681-6. [pmid: 1418829].
74 Reyes AJ, Leary WP, Acosta-Barrios TN, et al. Magnesium supplementation in hypertension treated with hydrochlorothiazide. Curr Ther Res, Clin Exp. 1984;36(2):332-40.
75 Avogaro P, Capri C, Cazzolato G, et al. Effects of the combination of nicotinic acid and propranolol in very low doses on blood lipids in man. Atherosclerosis. Sep. 1974;20(2):395-400. [pmid: 4369975].
76 Nordøy A, Bonaa KH, Sandset PM, et al. Effect of omega-3 fatty acids and simvastatin on hemostatic risk factors and postprandial hyperlipemia in patients with combined hyperlipemia. Arterioscler Thromb Vasc Biol. Jan. 2000;20(1):259-65. [pmid: 10634827].
77 Ferraro PM, Ferraccioli GF, Gambaro G, et al. Combined treatment with renin-angiotensin system blockers and polyunsaturated fatty acids in proteinuric IgA nephropathy: a randomized controlled trial. Nephrol Dial Transplant. Jan. 2009;24(1):156-60. [pmid: 18685141].
78 Isley WL, Miles JM, Harris WS. Pilot study of combined therapy with omega-3 fatty acids and niacin in atherogenic dyslipidemia. J Clin Lipidol. 2007;1(3):211-7. [pmid: 21291683].
79 Sutken E, Inal M, Ozdemir F. Effects of vitamin E and gemfibrozil on lipid profiles, lipid peroxidation and antioxidant status in the elderly and young hyperlipidemic subjects. Saudi Med J. Apr. 2006;27(4):453-9. [pmid: 16598319].
80 Micheletta F, Natoli S, Misuraca M, et al. Vitamin E supplementation in patients with carotid atherosclerosis: reversal of altered oxidative stress status in plasma but not in plaque. Arterioscler Thromb Vasc Biol. Jan. 2004;24(1):136-40. [pmid: 14592846].
81 Barbagallo M, Dominguez LJ, Tagliamonte MR, et al. Effects of vitamin E and glutathione on glucose metabolism: role of magnesium. Hypertension. Oct. 1999;34(4 Pt 2):1002-6. [pmid: 10523398].
82 Paolisso G, Gambardella A, Giugliano D, et al. Chronic intake of pharmacological doses of vitamin E might be useful in the therapy of elderly patients with coronary heart disease. Am J Clin Nutr. Apr. 1995;61(4):848-52. [pmid: 7702030].
83 McDowell IF, Brennan GM, McEneny J, et al. The effect of probucol and vitamin E treatment on the oxidation of low-density lipoprotein and forearm vascular responses in humans. Eur J Clin Invest. Nov. 1994;24(11):759-65. [pmid: 7890014].
84 Duffy SJ, O'Brien RC, New G, et al. Effect of anti-oxidant treatment and cholesterol lowering on resting arterial tone, metabolic vasodilation and endothelial function in the human forearm: a randomized, placebo-controlled study. Clin Exp Pharmacol Physiol. May. 2001;28(5–6):409-18. [pmid: 11380515].
85 Desideri G, Croce G, Tucci M, et al. Effects of bezafibrate and simvastatin on endothelial activation and lipid peroxidation in hypercholesterolemia: evidence of different vascular protection by different lipid-lowering treatments. J Clin Endocrinol Metab. Nov. 2003;88(11):5341-7. [pmid: 14602771].
86 De Caterina R, Cipollone F, Filardo FP, et al. Low-density lipoprotein level reduction by the 3-hydroxy-3-methylglutaryl coenzyme-A inhibitor simvastatin is accompanied by a related reduction of F2-isoprostane formation in hypercholesterolemic subjects: no further effect of vitamin E. Circ Cardiovasc Qual Outcomes. Nov. 12. 2002;106(20):2543-9. [pmid: 12427649].
87 Manuel YK, Vinckx M, Vertommen J, et al. Impact of Vitamin E supplementation on lipoprotein peroxidation and composition in Type 1 diabetic patients treated with Atorvastatin. Atherosclerosis. Aug. 2004;175(2):369-76. [pmid: 15262194].
88 Watson PD, Joy PS, Nkonde C, et al. Comparison of bleeding complications with omega-3 fatty acids + aspirin + clopidogrel--versus--aspirin + clopidogrel in patients with cardiovascular disease. Am J Cardiol. Oct. 15. 2009;104(8):1052-4. [pmid: 19801023].
89 Caso G, Kelly P, McNurlan MA, et al. Effect of coenzyme q10 on myopathic symptoms in patients treated with statins. Am J Cardiol. May. 15. 2007;99(10):1409-12. [pmid: 17493470].
90 Mauro VF, Mauro LS, Kleshinski JF, et al. Impact of ginkgo biloba on the pharmacokinetics of digoxin. Am J Ther. Jul. 2003;10(4):247-51. [pmid: 12845387].
91 Neil HA, Ceglarek U, Thiery J, et al. Impact of atorvastatin and omega-3 ethyl esters 90 on plasma plant sterol concentrations and cholesterol synthesis in type 2 diabetes: a randomised placebo controlled factorial trial. Atherosclerosis. Dec. 2010;213(2):512-7. [pmid: 21036355].
92 Nordøy A, Svensson B, Hansen JB. Atorvastatin and omega-3 fatty acids protect against activation of the coagulation system in patients with combined hyperlipemia. J Thromb Haemost. 2003;1(4):690-7. [pmid: 12871402].
93 Gosai P, Liu J, Doyle RT, et al. Effect of omega-3-acid ethyl esters on the steady-state plasma pharmacokinetics of rosuvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2947-53. [pmid: 19006471].
94 Bays HE, McKenney J, Maki KC, et al. Effects of prescription omega-3-acid ethyl esters on non--high-density lipoprotein cholesterol when coadministered with escalating doses of atorvastatin. Mayo Clin Proc. Feb. 2010;85(2):122-8. [pmid: 20118387].
95 McKenney JM, Swearingen D, Di SM, et al. Study of the pharmacokinetic interaction between simvastatin and prescription omega-3-acid ethyl esters. J Clin Pharmacol. Jul. 2006;46(7):785-91. [pmid: 16809804].
96 Balestrieri GP, Maffi V, Sleiman I, et al. Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Prog Med. Mar. 1996;87(3):102-5. [pmid: 8650428].
97 Hansen JB, Lyngmo V, Svensson B, et al. Inhibition of exercise-induced shortening of bleeding time by fish oil in familial hypercholesterolemia (type IIa). Arterioscler Thromb. Jan. 1993;13(1):98-104. [pmid: 8422345].
98 Svaneborg N, Kristensen SD, Hansen LM, et al. The acute and short-time effect of supplementation with the combination of n-3 fatty acids and acetylsalicylic acid on platelet function and plasma lipids. Thromb Res. Feb. 15. 2002;105(4):311-6. [pmid: 12031825].
99 Mueller BA, Talbert RL, Tegeler CH, et al. The bleeding time effects of a single dose of aspirin in subjects receiving omega-3 fatty acid dietary supplementation. J Clin Pharmacol. Feb. 1991;31(2):185-90. [pmid: 2010565].
100 d'Arcangues C, Piaggio G, Brache V, et al. Effectiveness and acceptability of vitamin E and low-dose aspirin, alone or in combination, on Norplant-induced prolonged bleeding. Contraception. Dec. 2004;70(6):451-62. [pmid: 15541406].
101 Hajda J, Rentsch KM, Gubler C, et al. Garlic extract induces intestinal P-glycoprotein, but exhibits no effect on intestinal and hepatic CYP3A4 in humans. Eur J Pharm Sci. Dec. 23. 2010;41(5):729-35. [pmid: 20933082].
102 Ioannidis JP, Trikalinos TA. The appropriateness of asymmetry tests for publication bias in meta-analyses: a large survey. CMAJ. Apr. 10. 2007;176(8):1091-6. [pmid: 17420491].
103 Peters JL, Sutton AJ, Jones DR, et al. Assessing publication bias in meta-analyses in the presence of between-study heterogeneity. Journal of the Royal Statistical Society: Series A (Statistics in Society). 2010;173(3):575-91.
104 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
105 Exploring the Science of Complementary and Alternative Medicine. National Center for Complementary and Alternative Medicine. Third Strategic Plan 2011–2015. U. S. Dept. of Health and Human Services. National Institutes of Health. 2011.
106 Von EE, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. Lancet. Oct. 20. 2007;370(9596):1453-7. [pmid: 18064739].
107 Leading causes of death. Centers for Disease Control and Prevention. http://www.cdc.gov/nchs/fastats/lcod.htm. Accessed June 20, 2011.
108 Leading causes of death. Statistics Canada. http://www40.statcan.gc.ca/l01/cst01/hlth36a-eng.htm. Accessed June 20, 2011.
109 Dietary supplement health and education act of 1994. [United States]. Office of Dietary Supplements. National Institutes of Health. 1994. Public law 103–417 103rd Congress.
110 Fontanarosa PB, Rennie D, DeAngelis CD. The need for regulation of dietary supplements--lessons from ephedra. JAMA. Mar. 26. 2003;289(12):1568-70. [pmid: 12672775].
111 Mas E, Mori TA, Coenzyme Q. (10) and statin myalgia: what is the evidence?. Curr Atheroscler Rep. Nov. 2010;12(6):407-13. [pmid: 20725809].
112 Whayne TF Jr. Statin Myopathy: Significant Problem With Minimal Awareness by Clinicians and no Emphasis by Clinical Investigators. Angiology. Jul. 2011;62(5):415-21. [pmid: 21421631].
113 Ramsay NA, Kenny MW, Davies G, et al. Complimentary and alternative medicine use among patients starting warfarin. Br J Haematol. Sep. 2005;130(5):777-80. [pmid: 16115136].
114 Coxeter PD, McLachlan AJ, Duke CC, et al. Herb-drug interactions: an evidence based approach. Curr Med Chem. Jun. 2004;11(11):1513-25. [pmid: 15180581].
115 Mills E, Wu P, Johnston BC, et al. Natural health product-drug interactions: A systematic review of clinical trials. Ther Drug Monit. 2005;27(5):549-57. [pmid: 16175124].
116 Izzo AA, Di Carlo G, Borrelli F, et al. Cardiovascular pharmacotherapy and herbal medicines: the risk of drug interaction. [Review] [81 refs]. Int J Cardiol. Jan. 2005;98(1):1-14. [pmid: 15676159].
117 Mannel M. Drug interactions with St John's wort : mechanisms and clinical implications. Drug Saf. 2004;27(11):773-97. [pmid: 15350151].
118 Caccia S, Gobbi M. St. John's wort components and the brain: uptake, concentrations reached and the mechanisms underlying pharmacological effects. Curr Drug Metab. Nov. 2009;10(9):1055-65. [pmid: 20214594].
119 Izzo AA, Ernst E. Interactions between herbal medicines and prescribed drugs: an updated systematic review. [Review] [189 refs]. Drugs. 2009;69(13):1777-98. [pmid: 19719333].
120 Flattery M. Herbal therapies and cardiac side effects. Prog Cardiovasc Nurs. 2008;23(4):187-90. [pmid: 19067984].
121 Kennedy DA, Seely D. Clinically based evidence of drugherb interactions: A systematic review. Expert Opin Drug Saf. 2010;9(1):79-124. [pmid: 20021292].
122 Trifiro G, Spina E. Age-related Changes in Pharmacodynamics: Focus on Drugs Acting on Central Nervous and Cardiovascular Systems. Curr Drug Metab. 2011. Apr. 18. [pmid: 21495972].
123 Corsonello A, Pedone C, Incalzi RA. Age-related pharmacokinetic and pharmacodynamic changes and related risk of adverse drug reactions. Curr Med Chem. 2010;17(6):571-84. [pmid: 20015034].
124 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. Ann Intern Med. Aug. 18. 2009;151(4):264-9. W64. [pmid: 19622511].
125 Ahlbom A, Alfredsson L. Interaction: A word with two meanings creates confusion. Eur J Epidemiol. 2005;20(7):563-4. [pmid: 16119427].
126 Sampson M, McGowan J, Cogo E, et al. An evidence-based practice guideline for the peer review of electronic search strategies. J Clin Epidemiol. Sep. 2009;62(9):944-52. [pmid: 19230612].
127 Reference Manager 12. [computer program]. Thomson Reuters. 2011.
128 Distiller SR. [computer program]. 2011.
129 The Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.0. [updated February 2008]. www.cochrane-handbook.org.
130 Struijk-Mulder MC, Ettema HB, Verheyen CC, et al. Comparing consensus guidelines on thromboprophylaxis in orthopedic surgery. [Review] [31 refs]. J Thromb Haemost. Apr. 2010;8(4):678-83. [pmid: 20040041].
131 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
132 Comprehensive Meta Analysis version 2.2.057 (New Jersey, USA). www.statsdirect.com. Accessed November 4, 2011.
133 R: A Language and Environment for Statistical Computing. Foundation for Statistical Computing. www.r-project.org. Accessed November 4, 2011.
134 Rowland M, Tozer TN. Absorption and disposition kinetics. 3rd ed. Philadelphia, PA. Lippincott Williams & Wilkins. 1995:11-52.
135 Lazzarin N, Vaquero E, Exacoustos C, et al. Low-dose aspirin and omega-3 fatty acids improve uterine artery blood flow velocity in women with recurrent miscarriage due to impaired uterine perfusion. Fertil Steril. Jul. 2009;92(1):296-300. [pmid: 18692841].
136 Ghatak A, Brar MJ, Agarwal A, et al. Oxy free radical system in heart failure and therapeutic role of oral vitamin E. Int J Cardiol. Dec. 6. 1996;57(2):119-27. [pmid: 9013263].
137 Eritsland J, Seljeflot I, Arnesen H, et al. Effect of long-term, moderate-dose supplementation with omega-3 fatty acids on monocyte procoagulant activity and release of interleukin-6 in patients with coronary artery disease. Thromb Res. Feb. 15. 1995;77(4):337-46. [pmid: 7740525].
138 Chan DC, Watts GF, Barrett PH, et al. Mechanism of action of a 3-hydroxy-3-methylglutaryl coenzyme a reductase inhibitor on apolipoprotein B-100 kinetics in visceral obesity. J Clin Endocrinol Metab. May. 2002;87(5):2283-9. [pmid: 11994377].
139 Haberka M, Mizia-Stec K, Mizia M, et al. N-3 polyunsaturated fatty acids early supplementation improves ultrasound indices of endothelial function, but not through NO inhibitors in patients with acute myocardial infarction: N-3 PUFA supplementation in acute myocardial infarction. Clin Nutr. Feb. 2011;30(1):79-85. [pmid: 20705373].
140 Chan DC, Nguyen MN, Watts GF, et al. Effects of atorvastatin and n-3 fatty acid supplementation on VLDL apolipoprotein C-III kinetics in men with abdominal obesity. The American journal of clinical nutrition. 2010;91(4):900-6. [pmid: 20181806].
141 Jonkers IJ, Smelt AH, Princen HM, et al. Fish oil increases bile acid synthesis in male patients with hypertriglyceridemia. J Nutr. Apr. 2006;136(4):987-91. [pmid: 16549462].
142 Fan L, Tao GY, Wang G, et al. Effects of Ginkgo biloba extract ingestion on the pharmacokinetics of talinolol in healthy Chinese volunteers. Ann Pharmacother. May. 2009;43(5):944-9. [pmid: 19401473].
143 Rombouts EK, Rosendaal FR, van der Meer FJ. Daily vitamin K supplementation improves anticoagulant stability. J Thromb Haemost. Oct. 2007;5(10):2043-8. [pmid: 17666020].
144 Gebuis EP, Rosendaal FR, van ME, et al. Vitamin K1 supplementation to improve the stability of anticoagulation therapy with vitamin K antagonists: a dose-finding study. Haematologica. Apr. 2011;96(4):583-9. [pmid: 21193422].
145 Ratanabanangkoon P, Guzman H, Almarsson O, et al. A high-throughput approach towards a novel formulation of fenofibrate in omega-3 oil. Eur J Pharm Sci. Apr. 23. 2008;33(4–5):351-60. [pmid: 18313905].
146 Bargossi AM, Grossi G, Fiorella PL, et al. Exogenous CoQ10 supplementation prevents plasma ubiquinone reduction induced by HMG-CoA reductase inhibitors. Mol Aspects Med. Suppl. 1994;15:s187-s193. [pmid: 7752830].
147 Lu WJ, Huang JD, Lai ML. The effects of ergoloid mesylates and ginkgo biloba on the pharmacokinetics of ticlopidine. J Clin Pharmacol. Jun. 2006;46(6):628-34. [pmid: 16707409].
148 Lankin VZ, Tikhaze AK, Kukharchuk VV, et al. Antioxidants decreases the intensification of low density lipoprotein in vivo peroxidation during therapy with statins. Mol Cell Biochem. Jul. 2003;249(1–2):129-40. [pmid: 12956408].
149 Sharma M, Ansari MT, Abou-Setta AM, et al. Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia. [Review] [51 refs]. Ann Intern Med. Nov. 3. 2009;151(9):622-30. [pmid: 19884623].
150 Rombouts EK, Rosendaal FR, van der Meer FJ. Influence of dietary vitamin K intake on subtherapeutic oral anticoagulant therapy. Br J Haematol. May. 2010;149(4):598-605. [pmid: 20151978].
151 Meyer BJ, Hammervold T, Rustan AC, et al. Dose-dependent effects of docosahexaenoic acid supplementation on blood lipids in statin-treated hyperlipidaemic subjects. Lipids. Mar. 2007;42(2):109-15. [pmid: 17393216].
152 Howe PR, Lungershausen YK, Cobiac L, et al. Effect of sodium restriction and fish oil supplementation on BP and thrombotic risk factors in patients treated with ACE inhibitors. J Hum Hypertens. Jan. 1994;8(1):43-9. [pmid: 8151606].
153 Budoff M. Aged garlic extract retards progression of coronary artery calcification. J Nutr. Mar. 2006;136(3 Suppl):741S-4S. [pmid: 16484554].
154 Chan DC, Watts GF, Nguyen MN, et al. Factorial study of the effect of n-3 fatty acid supplementation and atorvastatin on the kinetics of HDL apolipoproteins A-I and A-II in men with abdominal obesity. Am J Clin Nutr. Jul. 2006;84(1):37-43. [pmid: 16825679].
155 Chan DC, Watts GF, Mori TA, et al. Randomized controlled trial of the effect of n-3 fatty acid supplementation on the metabolism of apolipoprotein B-100 and chylomicron remnants in men with visceral obesity. Am J Clin Nutr. Feb. 2003;77(2):300-7. [pmid: 12540386].
156 Chan DC, Nguyen MN, Watts GF, et al. Effects of atorvastatin and n-3 fatty acid supplementation on VLDL apolipoprotein C-III kinetics in men with abdominal obesity. Am J Clin Nutr. Apr. 2010;91(4):900-6. [pmid: 20181806].
157 Chan DC, Watts GF, Barrett PHR, et al. Effect of atorvastatin and fish oil on plasma high sensitive c-reactive protein, interleukin-6 and tumor necrosis factor-alpha levels in obese subjects. Atherosclerosis. 2002;3(2):87.
158 Chan DC, Watts GF, Barrett PH, et al. Effect of atorvastatin and fish oil on plasma high-sensitivity C-reactive protein concentrations in individuals with visceral obesity. Clin Chem. Jun. 2002;48(6 Pt 1):877-83. [pmid: 12029003].
159 Maki KC, Dicklin MR, Davidson MH, et al. Baseline lipoprotein lipids and low-density lipoprotein cholesterol response to prescription omega-3 acid ethyl ester added to Simvastatin therapy. Am J Cardiol. May. 15. 2010;105(10):1409-12. [pmid: 20451686].
160 Nordøy A, Bonaa KH, Nilsen H, et al. Effects of Simvastatin and omega-3 fatty acids on plasma lipoproteins and lipid peroxidation in patients with combined hyperlipidaemia. J Intern Med. 1998;243(2):163-70. [pmid: 9566646].
161 Nordøy A, Hansen JB, Brox J, et al. Effects of atorvastatin and omega-3 fatty acids on LDL subfractions and postprandial hyperlipemia in patients with combined hyperlipemia. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2001;11(1):7-16. [pmid: 11383326].
162 Bays HE, Maki KC, Doyle RT, et al. The effect of prescription omega-3 fatty acids on body weight after 8 to 16 weeks of treatment for very high triglyceride levels. Postgrad Med. Sep. 2009;121(5):145-50. [pmid: 19820283].
163 Davidson MH, Macariola-Coad JR, McDonald AM, et al. Separate and joint effects of marine oil and simvastatin in patients with combined hyperlipidemia. Am J Cardiol. Sep. 15. 1997;80(6):797-8. [pmid: 9315596].
164 Lungershausen YK, Howe PR. Improved detection of a blood pressure response to dietary intervention with 24-hour ambulatory monitoring. Am J Hypertens. Dec. 1994;7(12):1115-7. [pmid: 7702808].
165 Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circ Cardiovasc Qual Outcomes. Dec. 17. 2002;106(25):3143-421. [pmid: 12485966].
166 Shitara Y, Sugiyama Y. Pharmacokinetic and pharmacodynamic alterations of 3-hydroxy-3-methylglutaryl coenzyme A (HMG-CoA) reductase inhibitors: drug-drug interactions and interindividual differences in transporter and metabolic enzyme functions. Pharmacol Ther. Oct. 2006;112(1):71-105. [pmid: 16714062].
167 Ashar BH, Rice TN, Sisson SD. Physicians' understanding of the regulation of dietary supplements. Arch Intern Med. May. 14. 2007;167(9):966-9. [pmid: 17502539].
168 Bent S. Herbal medicine in the United States: review of efficacy, safety, and regulation: grand rounds at University of California, San Francisco Medical Center. J Gen Intern Med. Jun. 2008;23(6):854-9. [pmid: 18415652].
169 Berman JD, Straus SE. Implementing a research agenda for complementary and alternative medicine. Annu Rev Med. 2004;55:239-54. [pmid: 14746520].
170 Cohen PA. American roulette--contaminated dietary supplements. N Engl J Med. Oct. 15. 2009;361(16):1523-5. [pmid: 19812394].
171 Cole MR, Fetrow CW. Adulteration of dietary supplements. Am J Health Syst Pharm. Aug. 1. 2003;60(15):1576-80. [pmid: 12951758].
172 de Smet PA. Health risks of herbal remedies: an update. Clin Pharmacol Ther. Jul. 2004;76(1):1-17. [pmid: 15229459].
173 Feifer AH, Fleshner NE, Klotz L. Analytical accuracy and reliability of commonly used nutritional supplements in prostate disease. J Urol. Jul. 2002;168(1):150-4. [pmid: 12050511].
174 Hamburg MA. Letter to manufacturers of dietary supplements. http://www.fda.gov/downloads/Drugs/ResourcesForYou/Consumers/BuyingUsingMedicineSafely/MedicationHealthFraud/UCM236985.pdf. Accessed September 30, 2011.
175 Desai D, Hasan A, Wesley R, et al. Effects of dietary supplements on aspirin and other antiplatelet agents: An evidence-based approach. Thromb Res. 2005;117(1–2):87-101. [pmid: 16115664].
176 Skalli S, Zaid A, Soulaymani R. Drug interactions with herbal medicines. Ther Drug Monit. Dec. 2007;29(6):679-86. [pmid: 18043467].
177 Mathew BC, Prasad NV, Prabodh R. Cholesterol-lowering effect of organosulphur compounds from garlic: a possible mechanism of action. Kathmandu Univ Med J (KUMJ ). Apr. 2004;2(2):100-2. [pmid: 15821374].
178 Wu T, Li Y, Bian Z, et al. Randomized trials published in some Chinese journals: how many are randomized?. Trials. 2009;10:46. [pmid: 19573242].
179 Shekelle PG, Morton SC, Suttorp MJ, et al. Challenges in systematic reviews of complementary and alternative medicine topics. Ann Intern Med. Jun. 21. 2005;142(12 Pt 2):1042-7. [pmid: 15968028].
180 Vickers A, Goyal N, Harland R, et al. Do certain countries produce only positive results? A systematic review of controlled trials. Control Clin Trials. Apr. 1998;19(2):159-66. [pmid: 9551280].