# Peer Reviewers

Mei Chung, Ph.D., M.P.H

Tufts University

Boston, MA

Rebecca Costello, Ph.D.

Office of Dietary Supplements

National Institutes of Health

Bethesda, MD

Arshad Jahangir, M.D.

University of Wisconsin

Milwaukee, WI

Donald Marcus, M.D.

Baylor College of Medicine

Houston, TX

Richard Nahin, Ph.D., M.P.H

Natuibak Center for Complementary and Alternative Medicine

National Institutes of Health

Bethesda, MD