# Key Informants

Brad Bradshaw

Patient/Consumer

Memphis, TN

Shiew-Mei Huang, Ph.D., FCP

Office of Clinical Pharmacology

Center for Drug Evaluation and Research

Food and Drug Administration

Silver Spring, MD

Alice Lichtenstein, D.Sc.

Professor of Nutrition Science and Policy

Tufts University

Boston, MA

Katharine Lillie, M.D., A.B.F.P

Medical Officer

Center for Drug Evaluation and Research

Food and Drug Administration

Silver Spring, MD

Edgar (Pete) Miller, M.D., Ph.D.

Associate Professor

Department of Medicine

Johns Hopkins Medical University

Baltimore, MD

Norman Stockbridge, Ph.D.

Center for Drug Evaluation and Research

Food and Drug Administration

Silver Spring, MD

Wendy Weber, N.D., Ph.D., M.P.H.

Program Officer

Division of Extramural Research

National Center for Complementary and Alternative Medicine

National Institutes of Health

Bethesda, MD