# Introduction

Vascular disease is a preventable condition that is the leading contributor to mortality in the United States107, and second place in Canada after cancer.108 Vascular disease includes peripheral vascular disease evident in hypertension; cardiovascular disease such as angina pectoris, myocardial infarction and heart failure; and cerebrovascular disease such as transient ischemic attack (TIA) and stroke.

The American Heart Association estimates that more than 81 million American adults (one-third of all American adults) have at least one form of cardiovascular disease (CVD), broadly defined to include all vascular disease.1 While there has been progress in the control of CVD, it demands huge investments from the health care system and represents great burdens and lost opportunities for individuals, families and society overall.

In addition to lifestyle and dietary recommendations, front line treatment for prevention and treatment of cardiovascular disease is primarily pharmaceutical, with patients requiring on average 6.3 concomitant prescription drugs, from on average 5.9 different drug classes, for primary and secondary prevention of the disease itself and management of associated comorbidities.2–4 The prescription drugs considered in this review are summarized in Table 1.

Table 1 Cardiovascular drugs of interest

Cardiovascular Drug Category | Drug Class | Drugs of Interest
Beta adrenergic antagonists | | acebutalol betaxolol bisoprolol carvedilol labetalol metoprolol | nadolol nebivolol pindolol propranolol sotalol timolol
Calcium channel antagonists | Dihydropyridine | amlodipine felodipine isradipine nicardipine | nifedipine nimodipine nisoldipine
Calcium channel antagonists | Non-Dihydropyridine | diltiazem | verapamil
Renin-angiotensin-aldosterone system antagonists | Angiotensin-converting enzyme inhibitors (ACE inhibitors) | benazepril captopril enalapril fosinopril lisinopril | moexipril perindopril quinapril ramipril trandolapril
Renin-angiotensin-aldosterone system antagonists | Angiotensin II receptor blockers (ARBs) | candesartan eprosartan irbesartan losartan | olmesartan telmisartan valsartan
Renin-angiotensin-aldosterone system antagonists | Renin inhibitors | aliskiren
Renin-angiotensin-aldosterone system antagonists | Aldosterone receptor antagonist | eplerenone spironolactone
Vasodilators | Central vasodilators | clonidine guanabenz | guanfacine methyldopa
Vasodilators | Direct vasodilators | diazoxide hydralazine | minoxidil
Vasodilators | Nitrates | isosorbide dinitrate
Vasodilators | | nitroglycerin
Vasodilators | Phosphodiesterase inhibitors | sildenafil tadalafil | vardenafil cilostazol
Vasodilators | Prostacycline | alprostadil epoprostenol | iloprost treprostinil
Vasodilators | Endothelin antagonist | bosentan | ambrisentan
Vasodilators | Miscellaneous vasodilators | papaverine isoxsuprine | rauwolfia alkaloids
Alpha adrenergic blockers | | doxazosin prazosin | terazosin
Antiarrhythmic drugs | Class 1a | disopyramide procainamide | quinidine
Antiarrhythmic drugs | Class 1b | mexilitine
Antiarrhythmic drugs | Class 1c | encainide flecainide | propafenone
Antiarrhythmic drugs | Class III | amiodarone dofetilide | dronedarone
Inotropic agents | | digoxin
Antilipemic agents | Bile acid sequestrants | colestipol colesevelam | cholestyramine resin
Antilipemic agents | Cholesterol absorption inhibitor | ezetimibe
Antilipemic agents | Fibric acid Derivatives | fenofibrate | gemfibrozil
Antilipemic agents | HMG-CoA reductase Inhibitors | atorvastatin fluvastatin lovastatin | pravastatin rosuvastatin simvastatin
Antilipemic agents | Miscellaneous | niacin>250 mg/day^*^
Anticoagulants | Coumarin derivatives | warfarin
Anticoagulants | Heparins | dalteparin enoxaparin | heparin tinzaparin
Antiplatelet agents | | acetylsalicylic acid (ASA) | clopidogrel ticlopidine
Diuretics | Loop diuretics | bumetanide ethacrynic acid | furosemide torsemide
Diuretics | potassium-sparing (K-sparing) | amilioride | triamterene
Diuretics | Thiazide | chlorothiazide hydrochlorothiazide methyclothiazide | bendroflumethazide polythiazide
Diuretics | Thiazide-like | chlorthalidone indapamide | metolazone

* Note: Niacin at not more than 250 mg/day doses was considered to be a dietary supplement.

Complementary and alternative medicine (CAM) refers to preventive and therapeutic modalities not generally considered to be part of conventional medicine,5 including dietary supplements. CAM utilization has increased dramatically in North America over the past decades in both the general and cardiovascular disease populations.6,7 The National Health Interview Survey (NHIS) indicated that a total of $34 billion in annual out-of-pocket expenditures was spent on CAM in 2007.^8^ Of this amount, 44 percent was spent on non-vitamin, non-mineral supplements.8 Estimates suggest that approximately one-third to nearly two-thirds of people suffering from heart failure or other cardiovascular disease use some form of dietary supplements, and are thus placed at risk for potential adverse events from interactions among pharmacologically active agents.7,9–11 To further complicate the issue, dietary supplements in the US are not regulated in the same manner as drugs. According to the Dietary Supplement Health and Education Act of 1994, manufacturers of supplements are not held to the same standards as manufacturers of prescription and over-the-counter drugs with respect to providing evidence of efficacy and safety prior to marketing.109 Furthermore, dietary supplements are not required to obtain United States Food and Drug Administration (FDA) approval, nor are there any FDA regulations that require evidence of purity, quality or composition prior to marketing. These products are available in pharmacies, grocery stores, health food stores, and via the internet, and are often consumed by patients without the knowledge of their care providers under the mistaken impression that supplements are safe, or without adverse effects. The purported benefits of dietary supplements are widespread and largely unsubstantiated. Many supplements have been suggested to be beneficial in various forms of cardiovascular disease (i.e., coenzyme Q10, omega-3 fatty acids and vitamin E for cardioprotection, garlic for hypercholesterolemia, hawthorn for congestive heart failure) with varying levels of evidence supporting these claims.110 The dietary supplements considered in this review, and the proposed mechanisms of action for selected supplements with purported cardiovascular benefits, are summarized in Table 2.

Table 2 Dietary supplements considered in this review

Supplement category | Supplement | Proposed Mechanism of Action | Purported Outcome Effect (italics – evidence unclear)
Vitamins and minerals | Niacin (≤ 250 mg/day)^*^ | Vasodilator, antioxidant, increases degradation and reduces synthesis of cholesterol | At higher doses Lipid lowering Anti-atherogenic
Vitamins and minerals | Vitamin A (beta carotene)^†^ | Lipid soluble antioxidant | Anti-atherogenic Cardioprotective
Vitamins and minerals | Vitamin D^†^ | Blood mineral homeostasis | Replete levels provide anti-hypertension, cardioprotective effect
Vitamins and minerals | Vitamin E | Lipid soluble antioxidant | Anti-atherogenic Cardioprotective With high doses, bleeding risk
Vitamins and minerals | Vitamin K | Involved in the endogenous production of clotting factors | Reversal of warfarin associated bleeding Stabilize warfarin dosing/titration
Vitamins and minerals | Magnesium | Essential cofactor in the Na-K-ATPase enzyme system, coronary vasodilator | Anti-arrhythmic Cardioprotective (thrombolytic) Controls hypertension
Herbs or other botanicals | Ginseng (American - Panax quinquefolius; Asian - Panax ginseng) | Largely unknown but proposed to have adaptogenic immunomodulatory and neuroprotective properties | “Tonic” improving exercise and mental capacity Anti-carcinogenic, stress reducing, and neuroprotective
Herbs or other botanicals | Echinacea (E. purpurea, E. angustifolia) | Immunostimulant | Symptom control for mild upper respiratory tract infections
Herbs or other botanicals | Garlic supplements (Allium sativum) | Inhibitor of HMG-CoA reductase, antioxidant, inhibitor of platelet aggregation | Lipid lowering Anti-atherogenic Antithrombotic Lowers blood pressure Possible bleeding risk
Herbs or other botanicals | Ginger supplements (Zingiber officinale) | Anti-inflammatory effect, inhibitor of platelet aggregation | Anti-emetic Anti-atherogenic Cardioprotective Antithrombotic
Herbs or other botanicals | Ginkgo (Ginkgo biloba) | Antioxidant Neuroprotectant Circulatory stimulant | Memory enhancement associated with dementia, Alzheimers Possible bleeding risk
Herbs or other botanicals | Omega-3 fatty acids | Anti-inflammatory Modulates VLDL and chylomycron metabolism | Lower triglycerides and CHD risk Anti-atherogenic High dose risks in CHD of bleeding, altered blood sugar, increased LDL-C, arrhythmia
Refined dietary substances, to increase the total dietary intake (e.g., enzymes or tissues from organs or glands) | Coenzyme Q10 | Cofactor in oxidative respiration Fat soluble antioxidant (Endogenous production decreases with age) | Antiatherogenic Used in cardiovascular conditions for deficiency (natural or statin-induced)
Refined dietary substances, to increase the total dietary intake (e.g., enzymes or tissues from organs or glands) | Red yeast rice extract | Inhibitor of HMG-CoA reductase | Lipid lowering
Refined dietary substances, to increase the total dietary intake (e.g., enzymes or tissues from organs or glands) | Resveratrol | Antioxidant Anti-inflammatory | Anti-cancer Cardioprotective
Refined dietary substances, to increase the total dietary intake (e.g., enzymes or tissues from organs or glands) | Hawthorn | Enhances intracellular calcium sensitivity in cardiomyocytes Increases degradation and reduces synthesis of cholesterol | Symptom control in CHF Lipid lowering Anti-atherogenic Ionotropic for arrhythmias

Notes: The primary source for this table is the Natural Standard database of Foods, Herbs and Supplements (http://naturalstandard.com/databases/herbssupplements/all/)

* Niacin at higher doses was considered to be a cardiovascular drug.

† The following vitamin analog forms are considered pharmaceutical drugs and were therefore excluded:

Analogs of vitamin A [bexarotene, fenretinide; 13-cis-retinoic acid (isotretinoin, Accutane); 9 –cis retinoic acid (Alitretinoin); and all trans retinoic acid (ATRA) (tretinoin)]; and

Analogues of vitamin D [Calcitriol; dihydrotachysterol (DHT); alfacalcidiol (1α-(OH)D3); calcipotriol; tacalcitol; 19-nor-1,25(OH)2D2 (19-norD2), oxacalcitriol (OCT), 22-oxa-1,25(OH)2D3; paricalcitol; doxercalciferol; 1α-hydroxyvitamin D2 (1α-(OH)D2); falecalcitriol]

Abbreviations: CHD = coronary heart disease; CHF = congestive heart failure; HMG-CoA = 3-hydroxy-3-methyl-glutaryl coenzyme A; LDL-C = low density lipoprotein cholesterol.

People at risk of or suffering from cardiovascular disease often take dietary supplements alongside prescribed drugs. The use of supplements may complement standard care, or may have a detrimental effect on the pharmacodynamics or pharmacokinetics of standard care. Given the uncertainty, and potential for harm, we need to understand better the risks and benefits, or lack thereof, associated with concomitant usage.

An example whereby the addition of a dietary supplement may confer benefit would be combining coenzyme Q10 with statin therapy. Amongst other actions, coenzyme Q10 has been shown to lower cholesterol, specifically low-density lipoprotein cholesterol,6 and while not proven, it is plausible that coenzyme Q10 reduces myalgia associated with statin therapy.111,112

Alternatively, the concomitant use of dietary supplements and cardiovascular drugs may lead to detrimental outcomes directly (i.e., either clinical or surrogate outcomes) or indirectly. For example, key factors within coagulation pathways are directly affected by garlic, fish oil, fenugreek, saw palmetto, Ginkgo biloba and danshen, which all have been shown to inhibit blood coagulation.10,113–115 However, increased bleeding is a serious potential risk when these dietary supplements are coupled with common anticoagulants like aspirin, warfarin, or ticlopidine. Conversely other supplements, even a seemingly innocuous one like green tea extract, that contains vitamin K, may counteract the anticoagulant effects of certain drugs and thus limit their effectiveness.116 Similarly, drug-dietary supplement interactions can negatively impact surrogate outcomes, as illustrated by metabolic enzyme induction. St. John’s wort for example, taken often for the treatment of depression, is a potent inducer of the CYP3A4 enzyme.117 This enzyme is involved in the oxidative metabolism of many synthetic drugs,114,115,118–121 including cardiac glycosides, beta-adrenergic blockers, calcium channel blockers, statins, angiotensin receptor antagonists, and anticoagulants.10,114,116 Increasing the metabolism of any of these drugs with use of this popular herbal product could reduce their effectiveness and potentially result in serious clinical consequences. Conversely, if prescription medication dosage is adjusted in the context of regular ingestion of a CYP3A4 enzyme inhibitor, then supplement cessation may result in excessive drug levels with other serious clinical consequences.

Concomitant use of dietary supplements and cardiovascular drugs may also affect clinically relevant outcomes indirectly. Risks for both non-adherence and interactions inevitably increase with the number of medications and supplements taken, and this is of greatest concern in the elderly.12,13 In addition to concerns of polypharmacy, the elderly also experience physiological changes that make them more susceptible to interactions, as a consequence of alterations in metabolism and excretion, affecting both pharmacodynamics and pharmacokinetics.122,123 The increasing morbidity that occurs within older populations suffering from CVD, in conjunction with greater potential for drug interactions, makes this subgroup particularly important to explore.

Thus, understanding the potential for drug-supplement interactions and consequences of such interactions is essential for clinicians and patients when prescribing medications, or advising or deciding to add dietary supplements to current medication and supplement regimes.

Incorporation in clinical practice of knowledge regarding the impact of concomitant use of cardiovascular disease medications and dietary supplements requires access to reliable drug-supplement information, as well as a commitment to documentation by clinicians.15,16

As a consequence of U.S. drug regulatory policy, much more research and data are available describing drug-drug interactions than drug-supplement interactions. Comprehensive systematic review of interactions between dietary supplements and drugs specifically in patients taking prescription medications for cardiovascular disease is clearly needed. Recently published systematic reviews addressing aspects related to this topic are not comprehensive, or focus on different populations of interest.115,119,121 This synthesis evaluates literature that addresses meaningful clinical outcomes, as well as important surrogate or intermediate outcomes, in the context of patients concurrently taking prescription drugs and dietary supplements for prevention and treatment of CVD.

The Key Questions examined in this review are as follows:

In adults taking cardiovascular drugs, what are the effects of concomitant use of specific dietary supplements (when compared to cardiovascular drugs alone or cardiovascular drugs and a different dietary supplement[s]) on:

1. clinical cardiovascular effectiveness/efficacy outcomes (e.g., mortality and specific cardiovascular or cerebrovascular conditions such as myocardial infarction [MI] and stroke)?
  a. Do the effect estimates of clinical cardiovascular outcomes vary by age, ethnicity, gender, or health status?
  b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for clinical cardiovascular outcomes?
2. intermediate cardiovascular efficacy outcomes (e.g., lipids, blood pressure, electrocardiographic measurements, serum markers, bleeding, and coagulation times)?
  a. Do the effect estimates of intermediate cardiovascular outcomes vary by age, ethnicity, gender, or health status?
  b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for intermediate cardiovascular outcomes?
3. clinical or intermediate harms outcomes (e.g., organ toxicity, serious adverse events, withdrawal due to adverse events)?
  a. Do the effect estimates of harms outcomes vary by age, ethnicity, gender, or health status?
  b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for harms outcomes?
4. pharmacokinetic outcomes (e.g., T1/2, area under the concentration curve [AUC]) of cardiovascular drugs of interest?
  a. Do the effect estimates of pharmacokinetic outcomes vary by age, ethnicity, gender, or health status?
  b. Is there a measurable interaction between cardiovascular drugs and dietary supplements for pharmacokinetic outcomes?