# Discussion

## Key Findings and Strength of Evidence

Billions of dollars are spent annually in the United States on complementary and alternative medicine (CAM), and a large portion of this expenditure is spent directly on dietary supplements.8 Given the high prevalence of cardiovascular disease and frequency of polypharmacy in this population, the risk of drug-supplement interactions deserves serious consideration primarily to avoid potential harm; either as a result of decreasing clinical effect of drugs, or increased toxicity. There is also a real possibility of drug interactions leading to synergistic effects and positive clinical outcomes. A more thorough understanding and knowledge of potential drug-supplement interactions is important to provide specific evidence-based recommendations that do not call for universal avoidance of all dietary supplements in conjunction with pharmaceutical treatments to treat or to prevent cardiovascular disease. Without such precision, recommendations may result in the avoidance of potentially beneficial supplements or more importantly might be more readily ignored, leading to greater likelihood for harm through negative interaction.

This systematic review identifies a considerable knowledge gap regarding the impact of combining dietary supplements with cardiovascular drugs in patients with cardiovascular disease. We sought to identify the direct and indirect evidence for cardiovascular drug-dietary supplement interactions and their outcomes, and found 69 unique studies contributed evidence for synthesis. With few exceptions there is insufficient evidence to draw any strong conclusions on particular interactions between dietary supplements and cardiovascular drugs. In addition to an overall lack of evidence, the studies that were included were generally not powered to assess the clinically relevant outcomes we pre-identified as being most relevant. In addition, many of the studies had important methodological limitations or were poorly generalizable to the population of relevance. The strength of the evidence found was frequently compromised by poor allocation concealment and issues related to blinding, study reporting, and potential for conflict of interest.

Evidence of direct impact (or lack thereof) on clinical outcomes such as heart attack or stroke is most useful for patients and providers. Twenty-two randomized controlled trials reported direct evidence of drug-supplement interactions on predetermined gradable clinical outcomes; however, most of the trials were grossly underpowered to demonstrate any real effect, and often were of moderate risk of bias, leading to insufficient grades for strength of evidence. We found evidence of impact on clinical outcomes from studies that evaluated two non-gradable outcomes. In one randomized controlled trial (RCT) postangiography restenosis rates were improved through consumption of 3.2 grams of eicosapentaenoic acid taken along with aspirin, dipyridamole, and calcium channel antagonists for a duration of six months.52 This finding was not supported by a similar but lower quality trial in India.51 The second non-gradable clinical outcome of note came from a large long-term pragmatic trial in which 19,934 women were randomized to 600 IU of vitamin E plus 100 mg/day of aspirin versus aspirin taken alone for 10 years. In this trial, no significant differences occurred between groups in a composite outcome consisting of nonfatal myocardial infarction, nonfatal stroke, and vascular death (RR 0.95 [95 percent confidence interval (CI) 0.79, 1.13]).39

Anticipating a paucity of evidence describing the influence of cardiovascular drug-dietary supplement interaction on meaningful clinical outcomes, we also sought indirect evidence of such interactions. Fifty-nine studies were identified that addressed intermediate cardiovascular outcomes (blood pressure, lipid profile, International Normalized Ratio (INR), metabolic syndrome, change in 10-year Framingham risk profile, and QT prolongation).Again, these were mostly underpowered studies of highly selected individuals, with considerable risk of study bias attributed to inadequate blinding, and allocation concealment. As a result, the most frequently graded strength of the evidence was “insufficient,” with a few outcomes graded as “low”.

In our review, we found some of the richest evidence on the combination of omega-3 fatty acids with cardiovascular drugs. Out of a total of 24 RCTs that measured both gradable and non-gradable surrogate outcomes, 13 assessed the combination of omega-3 fatty acids with statins (atorvastatin, simvastatin, lovastatin). From pooled results of six trials40,44,53,96,151,163 and five trials40,44,53,96,151 respectively, no beneficial or harmful effect on HDL-C or LDL-C was found (low strength of evidence). While the evidence for total cholesterol and triglycerides was inconclusive (i.e., statistically non-significant pooled estimates with wide 95 percent confidence interval), there appeared to be some trend indicating possible improvement in these outcomes for patients taking omega-3 fatty acids with statins, which might not have reached the level of statistical significance due to low power of the meta-analyses. Results regarding non-HDL-C and total cholesterol/HDL-C ratio were inconsistent across studies. In addition, there was evidence of low strength from one parallel arm RCT92 and one crossover RCT37 that systolic blood pressure was improved when statins were taken with omega-3 fatty acids.

The addition of omega-3 fatty acids to statins (only in participants with high baseline levels of TG) or the combination of aspirin and a calcium channel blocker with or without dipyridamole appears to reduce triglyceride levels but not HDL-C or LDL-C.40,51,52,76 It is likely that the triglyceride drop reflects the activity of omega-3 fatty acids alone rather than a synergistic or additive effect in combination with antiplatelet agents and calcium channel blockers. The combination of omega-3 fatty acids with ACE-inhibitors appears to have no significant effect on blood pressure and also demonstrates evidence consistent with omega-3 fatty acids having an independent benefit for triglyceride reduction.152 In patients with biopsy proven IgA nephropathy, a single 6-month duration RCT found that the inclusion of omega-3 fatty acids with renin–angiotensin system blockers reduced the degree of proteinuria in comparison to the cardiovascular drugs.77 In the only trial that assessed for pharmacodynamic interaction between warfarin and omega-3 fatty acids, there was no evidence of differences in coagulation based on INR; however this was a very small study (11 participants) and neither data nor confidence intervals were provided to evaluate this further.55

The inclusion of coenzyme Q10 with statin drugs seems to have no significant effect on any parameter of lipid profile predetermined to be a gradable outcome (high- or low-density lipoprotein-cholesterol (HDL-C or LDL-C), triglycerides, and non-HDL-C). Only one study explored the effect of coenzyme Q10 with fenofibrate on cholesterol levels and hypertension.58 Although the trial failed to demonstrate any interaction, the RCT was underpowered to find any significant results. A similar situation applies to a small sized RCT comparing the combination of coenzyme Q10 with an angiotensin-converting enzyme (ACE) inhibitor on ejection fraction among patients with heart failure.54 One RCT of 60 patients with coronary artery disease (CAD) suggests that the combination of 4 g/day of garlic oil taken with nitrates has a positive effect on HDL-C levels compared with nitrates taken alone.62 This result, while statistically significant, may not be clinically meaningful and likely does not reflect an interaction between the two agents so much as an isolated effect of garlic, since nitrates are not known to affect HDL-C.

In a single RCT conducted in an elderly population (at least 65 years), platelet adhesion (a non-gradable outcome) decreased significantly through concomitant use of vitamin E with aspirin.49 In another RCT, supplementation with vitamin E in patients taking nifedipine led to a significant beneficial change in LDL-C (low strength of evidence).Again, we suspect this is an isolated effect of the dietary supplement rather than reflective of an interaction between vitamin E and nifedipine itself. Finally, supplementation with low doses of vitamin K (0.1 to 0.15 mg/day) in patients anticoagulated with warfarin appeared to provide stability to INR titration and increase time within the therapeutic range based one study in participants of unknown ethnicity.41 The stabilizing effect of vitamin K was independent of pre-specified subgroup status including gender (male/female) and age (younger or older than 65 years) in one of the studies where this was evaluated.159

Outcomes related to harms associated with drug interactions between dietary supplement and cardiovascular drugs were reported in 57 unique studies, most of which were considered to be at moderate risk of bias. Gradable harms outcomes included serious adverse events, withdrawal due to adverse events, bleeding, renal dysfunction, and hepatotoxicity. Of the studies that assessed harms outcomes, reported adverse events ranged from mild (e.g., flatulence) to severe (e.g., leucopenia, major bleeding), but for all the gradable outcomes for which evidence was found, the strength of evidence was judged insufficient primarily due to a lack of power contributing to the possibility of a type II error. Furthermore, very few studies systematically screened for predefined adverse events. With respect to non-gradable harms outcomes, results on benefit of coenzyme Q10 in reducing statin induced myopathic pain were inconclusive. Two pilot trials with small sample sizes reported conflicting results regarding myopathic pain. One of these trials,89 reported potential benefit of coenzyme (100 mg/day) added to statins (varying types and doses) compared with vitamin E added to statins. The other study,38 reported no significant differences in reduction of myalgia or number of participants tolerating statin between groups treated with combination of coenzyme Q10 (200 mg/day) or simvastatin (10 to 40 mg/day) alone. In one RCT significantly elevated fasting blood glucose occurred in the omega-3 fatty acids plus statins group versus the statins alone group.40

Finally, evidence for interactions between cardiovascular drugs and dietary supplements was sought from studies that assessed for direct changes in drug pharmacokinetics when combined with any of the supplements in question. Gradable pharmacokinetic outcomes included area under the concentration curve (AUC), maximum concentration (C_max_), clearance, and drug half-life. Eleven studies contributed pharmacokinetic evidence, all of which had moderate risk of bias. We found no clear evidence of drug-supplement pharmacokinetic interaction. Evidence was either low or insufficient to rule in or out clinically important pharmacokinetic interactions, or showed no clinically important interactions. The following findings were graded as having low strength of evidence. Coadministration of Echinacea with warfarin may reduce the AUC of warfarin with statistical significance, but warfarin was still within the range of clinical bioequivalence. Supplementation with Ginkgo biloba, garlic, Panax ginseng or ginger extracts in patients taking warfarin does not appear to change measurably any clinically relevant warfarin pharmacokinetics. American ginseng demonstrated a shift in AUC of warfarin; however the clinical significance of this shift is not clear. No pharmacokinetic interaction between G.biloba and ticlopidine was identified. Finally interactions between omega-3 fatty acids and statins (rosuvastatin, simvastatin, and atorvastatin) are unclear – while for some important pharmacokinetic outcomes there was evidence of no clinically important interactions (low strength of evidence), others remained inconclusive (insufficient evidence). No studies examined pharmacokinetic interactions between coenzyme Q10, magnesium, niacin (up to 250 mg/day), red yeast rice extract, resveratrol, vitamin A, vitamin D (with or without calcium supplementation), vitamin E, and vitamin K with any of the cardiovascular drugs.

## Clinical Context and Applicability of Evidence for Decisionmaking

The purpose of this review was to synthesise the available evidence regarding the clinical significance of drug interactions between dietary supplements and cardiovascular drugs, in order to provide recommendations for medication management to care providers and patients. Ideally, any such recommendations would arise from the synthesis of studies that evaluate meaningful clinical outcomes in the context of relevant drug interactions. In the absence of studies that provide enough data to make strong recommendations we employed a search for a hierarchy of outcomes including meaningful clinical outcomes (i.e., stroke, myocardial infarction), intermediate or surrogate outcomes (i.e., lipid profile, anticoagulation parameters), harms outcomes (i.e., bleeding, adverse drug effects) and finally, pharmacokinetic evidence of interaction (i.e., changes in AUC, drug clearance). Decision makers should be aware that when a strong recommendation cannot be supported by clinical outcome data, recommendations can still be made with intermediate, harms and pharmacokinetic outcomes but the strength of these recommendations cannot be considered to be equal. The correlation between surrogate and clinical outcomes relies on the clinical rationale that surrogate outcome measures truly predict the clinical outcome. Anticipating that the evidence linking drug interactions to clinical outcomes would be sparse, we were careful to ensure appropriate selection of intermediate, harms and pharmacokinetic outcomes by soliciting expert opinion and a strong clinical rationale for each chosen surrogate outcome. Our findings organised according to this hierarchy is provided in Table 56.

Table 56 Summary and hierarchy of significant findings

Strength of Evidence | Dietary Supplement | Cardiovascular Drug(s) | Outcome | Findings
Clinical Outcomes – None with strength of evidence “Low” or better
Intermediate Outcomes
Low | CoEnzyme Q10 | Fenofibrate | HDL-C | No additional benefit
Low | Garlic | Warfarin | HDL-C | In favor of combination
Low | Garlic | Nitrates | HDL-C | In favor of combination
Low | Omega-3 fatty acids | Statins | HDL-C | No additional benefit
Low | Omega-3 fatty acids | Statins | LDL-C | No additional benefit
Low | Omega-3 fatty acids | Statins | TG | In favor of combination
Low | Omega-3 fatty acids | Statins | Systolic blood pressure | In favor of combination
Low | Omega-3 fatty acids | Statins | Diastolic blood pressure | No additional benefit
Low | Omega-3 fatty acids | ACE inhibitors | Systolic blood pressure | No additional benefit
Low | Omega-3 fatty acids | ACE inhibitors | Diastolic blood pressure | No additional benefit
Low | Omega-3 fatty acids | Calcium channel blockers and ASA | Triglycerides | In favor of combination
Low | Omega-3 fatty acids | Calcium channel blockers and ASA and dipyridamole | LDL-C | In favor of combination
Low | Omega-3 fatty acids | Calcium channel blockers and ASA and dipyridamole | Triglycerides | In favor of combination
Low | Vitamin E | Nifedipine | LDL-C | In favor of combination
Low | Vitamin E | Nifedipine | Triglycerides | In favor of combination
Low | Vitamin K | Coumarin derivatives | % time in INR therapeutic range | In favor of combination
Low | Vitamin K | Coumarin derivatives | Variability (SD) of INR | In favor of combination
Low | Vitamin K | Coumarin derivatives | N in therapeutic range (INR) 100% of the time | In favor of combination
Low | Vitamin K | Coumarin derivatives | N achieving target INR | In favor of combination
Low | Vitamin K | Coumarin Derivatives | N achieving stable INR | In favor of combination

Strength of Evidence | Dietary Supplement | Cardiovascular Drug(s) | Outcome | Findings
Harms Outcomes – None with strength of evidence “Low” or better
Pharmacokinetic Outcomes
Low | Echinacea | Warfarin | AUC, Cmax, Half-life, clearance | No evidence of interaction
Low | Garlic | Warfarin | AUC, half-life, clearance | No evidence of interaction
Low | Ginger | Warfarin | AUC, Cmax, half-life, clearance | No evidence of interaction
Low | Ginkgo biloba | Ticlopidine | AUC, half-life, Cmax | No evidence of interaction
Low | Ginkgo biloba | Warfarin | AUC, Cmax, half-life, clearance | No evidence of interaction
Low | Ginseng | Warfarin | Cmax, half-life, clearance | No evidence of interaction
Low | Omega-3 fatty acids | Rosuvastatin, Atorvastatin | AUC, Cmax | No evidence of interaction

Abbreviations: AUC = area under the curve; Cmax = maximum concentration; HDL-C = high density lipoprotein-cholesterol; INR = International Normalized Ratio; LDL-C = low density lipoprotein cholesterol.

Furthermore, interpretation of this report and assessment of its clinical relevance requires acknowledgment of some of the limitations of the data within. The reader must recognize that dietary supplements in the US are not regulated in the same manner as prescription drugs. This has led to some fundamental barriers to conducting and interpreting clinical research with dietary supplements. Manufacturers of supplements are not held to the same standards as manufacturers of prescription and over-the-counter drugs with respect to providing evidence of efficacy and safety prior to marketing.109 Dietary supplements do not require FDA approval, nor are there any FDA regulations that require evidence of purity, quality or composition prior to marketing. This has resulted in a lack of standardization of these products among manufacturers and even among products from a single manufacturer. Products that claim to have standardized composition of active ingredients (if known) most often cannot claim standardization of biologic activity. Furthermore, postmarketing assessment of “standardized” herbal preparations often reveal that claims on the product label are not true.167–170 These products are available in pharmacies, grocery stores, health food stores, and via the internet, and are sold by many different vendors. Lack of manufacturing regulations, and labelling standards may result in significant differences between products, unbeknownst to the consumer, that limit the external validity of clinical trials. In addition to concerns over quality and quantity of active ingredients, concerns over purity can be troubling. Botanical products and herbal remedies can on occasion be contaminated with heavy metals or interact with other medications. If present, this interference puts patients at risk for toxicity and interactions from other substances that otherwise would be attributed to the supplement.170–173 Finally, there is little reliable, published information regarding the safety of dietary supplements. Until only recently, manufacturers of dietary supplements were not obliged to report serious adverse events. This represents a gross discrepancy compared with what is required of prescription drugs. Although, the FDA has recently taken steps to make serious adverse event reporting mandatory, most of the data in this report predates that mandate, and even since 2008 when the mandate was put in place, the FDA believes that adverse events are significantly underreported.174

Most of the studies included in this review that measured clinical outcomes provided inconclusive findings, primarily due to limitations in study design (underpowered), and risk of bias (allocation concealment, randomization). The weakness of the evidence itself, and its clinical relevance is compounded by a general lack of evidence on dietary supplement-cardiovascular drug interactions in the literature overall. Ultimately this limited information makes it impossible to translate our findings into clear advice and tools for clinical decision-making. The limited evidence also did not permit an effective dose-response evaluation to distinguish dose thresholds at which interactions may result.

Without an adequate evidence base from the literature, variability in effects across clinically important subgroups (i.e., stratified by age, ethnicity, gender or health status) could not be assessed. The evidence on clinical outcomes was generally inconclusive and applicability of inconclusivity was meaningless. The trials were generally efficacy studies in highly selected cardiovascular populations lasting for a short period of observation, along with some single-dose studies in healthy individuals. Reported benefits or “lack of harm” from studies not powered to assess these outcomes, or those in healthy volunteers may not translate into efficacy or safety in the elderly population with cardiovascular disease. As such we are unfortunately left with the unsatisfying yet fundamentally important call for more research with focused consideration and evaluation of dietary supplement-drug interaction in both clinical and observational studies.

The limit of good clinical outcomes data on which to base recommendations, leads to predicting hypothetical interactions wherein indirect evidence is the most prevalent albeit least reliable information source. The study of pharmacokinetic outcomes and changes in these outcomes are best suited to address this area. However, evidence of pharmacokinetic alterations due to interaction may not translate into altered clinical effectiveness or harms even if well characterized. Pharmacokinetic studies are generally conducted in healthy volunteers and as such the evidence may not reflect the compromised physiologic processes of the elderly and the diseased.

With relatively limited findings given its scope, the value in this review is that it points out the need for further consideration of the question of interactions and comparative effectiveness for dietary supplements when considered in conjunction with cardiovascular drugs. Aside from further research in the area of dietary supplement-drug interactions, better documentation of supplement use by cardiovascular patients is critical to better define where interactions may result in clinically relevant sequelae.

## Review of Other Systematic Reviews

Recent systematic reviews related to the topic of dietary supplement-drug interactions do not address the same scope, are not comprehensive, or involve different populations of interest. Mills and colleagues published a systematic review in 2005 focused on the effect of natural health products on the metabolism of conventional medicines.115 Their focus was not cardiovascular drugs or patients in particular, and they described the evidence for dietary supplement–drug interactions for any conventional drug category. The evidence in the review is compiled from 41 pharmacokinetic studies. Mills’ review identified a lack of evidence supporting any interaction between coenzyme Q10 and warfarin, Ginkgo biloba and warfarin, and G. biloba and digoxin. These finding are consistent with those in our review. Both reviews identified a shift in AUC of INR when American ginseng was taken in conjunction with warfarin; however, we question the clinical significance of this finding.

Also in 2005, Desai and colleagues published a review of interactions between dietary supplements and antiplatelet agents.175 The review included both clinical trials and case reports. With respect to the dietary supplements considered in our review, Desai concluded that omega-3 fatty acids given in conjunction with aspirin led to comparatively significant reductions in ADP induced platelet aggregation, blood platelet count, thromboxane B2, and restenosis rates, and also led to a prolongation in bleeding time. The addition of vitamin E to aspirin led to comparatively significant reductions in platelet adhesion, ischemic stroke, recurrent episodes of TIA, and prolonged dental bleeding time. Unlike our review, the Desai review did not attempt to grade the outcomes extracted and while findings are largely consistent, the graded evaluation we completed did not allow the same confidence in conclusions regarding the interactions from these agents based on the directness and overall strength of evidence.

In one of the more relevant reviews published by Izzo and colleagues in 2005, Pubmed was searched to Feb 2003 for drug interactions with cardiovascular drugs, and evidence was included from case reports (43 studies) and clinical trials (eight studies).116 This review did not systematically evaluate the quality of evidence, nor was there any grading of the strength of their recommendations. For example, drug interactions between Ginkgo, garlic, and ginseng were identified based on few or single case reports while our review found low or insufficient evidence of any interaction from trials of both direct and indirect evidence. In a 2009 review by Izzo and Ernst, the evidence was again extracted from case reports (41 studies) and clinical studies (17 studies) but did not focus on drug interactions with cardiovascular drugs.119 None of their 17 clinical studies provided evidence for dietary supplement-cardiovascular drugs within the scope of our review.

Skalli and colleagues published a review in 2007, wherein the majority of evidence for supplement-drug interactions was generated from case reports, and there was no focus on cardiovascular drugs.176 The authors identified interactions between warfarin and all of the following: ginger; Ginkgo biloba; garlic; and ginseng. This was again primarily from single case reports or case series. Our review found no evidence of such interactions from clinical trials providing direct or indirect evidence (insufficient or low levels of evidence). The reviewers also suggest that G. biloba can counteract the effect of thiazide diuretics by increasing blood pressure (based on case report data). We found insufficient evidence to support this claim.

The most recent systematic review on dietary supplement-drug interactions was published in 2010 by Kennedy and Seely, and examined herb-drug interactions identified from trials whereby herbal impact on hepatic metabolism via cytochrome P450 isoenzymes could be ascertained.121 In this review, the target population was not specific to cardiovascular patients or drugs, and the review evaluated indirect evidence limited to herbs metabolized via the cytochrome P450 system. While the information from this review provides an evaluation of primarily indirect data regarding possible pharmacokinetic interactions, the results do not overlap meaningfully with the findings from our review, which addresses only direct evidence for pharmacokinetic interaction.

## Limitations of the Review

Limitations of our systematic review process include our restriction of the number of dietary supplements of interest to 16 of the most commonly used; this was necessary given limitations of resources and review time. Up to 30 percent of included studies were assessed to have the potential for financial conflict of interest and approximately 45 percent did not report funding information. Given the uncertainties involved in interpreting asymmetry tests for publication bias in most reviews, especially in presence of heterogeneity in effect estimates, we did not plan to investigate publication bias in this review.102,103 In fact, a recent recommendation is that tests for funnel plot asymmetry should be used only in a minority of meta-analyses including at least ten studies of unequal sizes per analysis without substantial heterogeneity in their effect sizes.104 However, other means of evaluating publication bias and selective outcome reporting exist, such as comparing publications with study protocol, which we did not adopt because of time and resource limitations. Seemingly, another limitation could be the exclusion of indirect evidence of drug interactions derived from surrogate measures such as alterations in probe drug metabolism, that highlight effects on enzymes involved in drug metabolism.121 As such, evidence traditionally originates in healthy volunteers; applicability of such evidence would have been as much of a concern as for the pharmacokinetic outcomes we examined, the applicability of which was restricted to healthy volunteers with uncompromised drug metabolism. In order to make causal inferences possible for translation into practice, we also excluded combinations of multiple dietary supplements with cardiovascular drugs. For example, a given combination of multivitamins coadministered with a cardiovascular drug(s) would be limited both in causal inference of supplement-drug(s) interactions and applicability to the specific doses and combinations of vitamins employed as intervention in the study.

Empiric evidence indicates that authors are more likely to report in an international English-language journal if results are positive, while publishing negative findings in German-language literature.177 We restricted eligibility criteria to English and German language records. We are unsure as to the magnitude (if any) and direction of language bias introduced as a result of excluding Chinese language literature for several reasons. First, traditional Chinese, and Ayurvedic medications, which are often concoctions of many herbs, were not included in this review. Secondly, most reports of randomized controlled trials published in Chinese journals lack an adequate description of randomization, and many non-randomized controlled trials have been published as randomized controlled trials.178 Thirdly, negative CAM findings are more likely to be published in mainstream medical journals (that is, English-language journals), while positive CAM findings are more likely to be published in CAM journals (which tend to be non–English-language journals).179 Lastly, there is evidence that countries such as China, Japan, Russia, and Taiwan publish more CAM studies with positive results than studies with negative results; this imbalance may reflect publication bias.180

## Conclusions

With limited data to discern evidence on dietary supplement-drug interactions, it is difficult to provide clear guidance to clinicians and patients regarding advice on the choices to be made in this area. Drug interactions that may result in positive or negative outcomes likely exist, and occur, but the evidence available and identified in this review is insufficient to provide clinical recommendations with confidence. The strength of evidence that we did find was low at best, with poor grading resulting from risks of bias, and small sample sizes greatly increasing the risk of type II error. In addition, the etiology for results are difficult to determine effectively as changes in a measured outcome could be due to either a real therapeutic effect that comes from the dietary supplement itself or be due to an interaction between the drug and the supplement in question.

With these caveats in mind, and the fact that the most reliable data comes from indirect intermediate outcomes associated with clinical results, the following is a summary of the clearer indications of interactions from the evidence reviewed:

- Omega-3 fatty acids (2 to 4 g/day) from fish and/or supplements likely do not interfere with the efficacy of statin therapy or calcium channel blockers in presence of antiplatelet agents, and may provide independent benefit in resolving hypertriglyceridemia.
- Vitamin K (0.1 to 0.15 mg/day) may help to stabilize INR when given with warfarin.
- Garlic (4 to 10 g/day) may not interact negatively with nitrates and warfarin and may confer independent benefit in improving HDL and total cholesterol.

Our confidence, however, in the validity and reproducibility of these findings is low.

## Limitations of the Evidence Base

The literature search applied in this review was comprehensive in exploring multiple sources for human level evidence, yet despite this, there was a decided lack of relevant evidence. The available literature came primarily from small trials of highly selected patients and subjects that limited external validity. While there was data from which we can derive a sense of lack of interaction in many cases, the small size of the trials made it impossible to ascertain the potential for a true clinical interaction. Had the trials been adequately powered, evidence of harm or interaction may have been seen.

The internal validity of most trials was compromised due to flawed designs, lack of appropriate allocation concealment, and risk of bias. There were very few examples where a formal assessment of statistical interaction was completed. One notable exception came from a trial whereby a decrease in triglyceride levels due to combination of omega-3 fatty acids with niacin led to twice the additive effect of the each therapy alone, indicating the possibility for synergy through concurrent use.78 In the absence of corroborating pharmacokinetic evidence or assessment for interaction, it is often impossible to determine whether a difference in outcome was due to a true pharmacological interaction, or due to more independent combined, or possibly counteracting therapeutic effects. As the goal of this synthesis work was not to complete a comparative effectiveness analysis of dietary supplement versus drugs for cardiovascular disease we did not formally assess for these comparative therapeutic effects.

In terms of the pharmacokinetic evidence assessing Key Question 4, most of the research was conducted on healthy young adults. Thus this level of evidence may not be applicable to older patients taking cardiovascular drugs due to possible differences in metabolism and the existence of comorbidities.

One of the principal limitations of the trials we evaluated was the fact that they were very small and thus susceptible to type II error. A slimly reassuring corollary to this is that if there was a real and dramatic clinical impact due to an interaction then some clinical effect would likely have shown up despite being underpowered for smaller effect sizes. Of greater concern are possible interactions that could arise through polypharmacy of prescription drugs, a situation all too common, in particular for the elderly population.

## Future Research Recommendations

Given the important gap in research in the area of dietary supplement-drug interactions there should be a strategic investment in building research capacity to address relevant questions. With the continued burden of cardiovascular disease in North America, this issue is not going to go away and will likely increase in magnitude if the public continues to increase their use of dietary supplements for self-care.

A focused research strategy regarding dietary supplement-cardiovascular drugs could consider a number of recommendations arising from this review:

1. First and foremost, future research with dietary supplements should involve substances for which the identity of the agents can be clearly ascertained and the chemical composition well characterized, and ideally standardized. If the active ingredients or biologic activity of these substances is not known then studies to characterize these variables, identify mechanisms of action and describe safety should precede clinical efficacy studies. According to the 2011–2015 strategic plan of the National Center for Complementary and Alternative Medicine (NCCAM), clinical trials of dietary supplements will not be supported without documentation of biology and mechanism of action105;
2. As extant literature is largely based on few small size efficacy studies of limited internal validity examining intermediate outcomes, future supplement-cardiovascular drug interaction trials should focus on meaningful clinical outcomes, be appropriately powered and rigorously conducted and reported, and provide precise measurements of both clinical effectiveness and harms outcomes;
3. Most studies were conducted in speciality settings, excluded patients with comorbidities, or uncontrolled comorbidities, and did not include ethnic and racial minorities; prospective trials should be representative of the population taking cardiovascular drugs in terms of comorbidities, setting, and racial distribution. They should also collect data and undertake subgroup analysis for age, gender, race, comorbidities (e.g., liver or renal compromise), and genotypic polymorphisms of the cytochrome P450 enzyme;
4. A substantial number of pharmacokinetic interaction studies did not report and analyze pharmacokinetic outcomes as per Food and Drug Administration guidance for bioequivalence studies.30 As such future experiments of drug interactions must evaluate pharmacokinetic outcomes as geometric mean ratios with predefined margins of bioequivalence. This would help in interpretation of statistically significant and nonsignificant outcomes in terms of clinical significance;
5. Given a dearth of studies examining interactions between specific supplements and cardiovascular drugs, future clinical trials and observational studies that explore the effect of cardiovascular drugs should additionally assess the use of dietary supplements, and include this in the reporting of results. One way to facilitate this would be to consider inclusion of inquiry for dietary supplement use and other CAM care in reporting guidelines such as CONSORT;
6. Phase I trials of cardiovascular drugs should include older populations, and if possible a pharmacokinetic assessment that includes dietary supplement usage;
7. As subgroups were underrepresented in existing studies, future studies investigating supplement-drug interactions should examine vulnerable subgroups such as the elderly, those with compromised renal and liver functions, and patients with multiple comorbidities;
8. Where possible, comparative effectiveness studies should include a statistical analysis for supplement drug interactions, and the trials should be powered accordingly;
9. Until well powered, experimental studies are conducted to examine dietary supplement-drug coadministration, evidence from well-conducted prospective observational studies should be sought. Observational studies compliant with STROBE guidelines should be powered appropriately to address predefined endpoints of both efficacy and safety in a naturalistic setting, where the population sampled is reflective of the population in whom this data would be meaningful;106 and
10. Given the difficulty and resource intensive nature of clinical trials, other sources of data should be considered to derive information regarding drug-dietary supplement interactions. Possibilities include synthesis of reports of adverse events made to both FDA and the Pharmacovigilance program at Health Canada. In addition, electronic health record linkages between databases of dietary supplement use and cardiovascular drug prescription may also add to the sparse evidence of supplement-cardiovascular drug interaction that currently exist.