# Data Extraction Forms

Appendix E outlines in detail all of the questions that were used in screening the literature and ultimately determined whether a study was included or excluded. Furthermore, all data extracted from each study are also listed in this appendix.

DSCI: Level 1, Broad Screen Form

DSCI: Level 2, Abstract Screen Form

DSCI: Level 3, Full Text Screening Form for Key Questions 1 to 4

DSCI: General Characteristics Form for Experimental Studies

DSCI: Statistical Interaction Form

DSCI: Continuous Outcomes Form

DSCI: Dichotomous Outcomes Form

DSCI: Continuous Outcomes Form for Cross-Over Studies

DSCI: Dichotomous Outcomes Form for Cross-Over Studies

## References

1 Abdul MI, Jiang X, Williams KM, et al. Pharmacokinetic and pharmacodynamic interactions of echinacea and policosanol with warfarin in healthy subjects. Br J Clin Pharmacol. May. 2010;69(5):508-15. [pmid: 20573086].
2 Aruna D, Naidu MU. Pharmacodynamic interaction studies of Ginkgo biloba with cilostazol and clopidogrel in healthy human subjects. Br J Clin Pharmacol. Mar. 2007;63(3):333-8. [pmid: 17010102].
3 Avogaro P, Capri C, Cazzolato G, et al. Effects of the combination of nicotinic acid and propranolol in very low doses on blood lipids in man. Atherosclerosis. Sep. 1974;20(2):395-400. [pmid: 4369975].
4 Balestrieri GP, Maffi V, Sleiman I, et al. Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Prog Med. Mar. 1996;87(3):102-5. [pmid: 8650428].
5 Barbagallo M, Dominguez LJ, Tagliamonte MR, et al. Effects of vitamin E and glutathione on glucose metabolism: role of magnesium. Hypertension. Oct. 1999;34(4 Pt 2):1002-6. [pmid: 10523398].
6 Bays HE, McKenney J, Maki KC, et al. Effects of prescription omega-3-acid ethyl esters on non--high-density lipoprotein cholesterol when coadministered with escalating doses of atorvastatin. Mayo Clin Proc. Feb. 2010;85(2):122-8. [pmid: 20118387].
7 Bays HE, Maki KC, Doyle RT, et al. The effect of prescription omega-3 fatty acids on body weight after 8 to 16 weeks of treatment for very high triglyceride levels. Postgrad Med. Sep. 2009;121(5):145-50. [pmid: 19820283].
8 Bender NK, Kraynak MA, Chiquette E, et al. Effects of marine fish oils on the anticoagulation status of patients receiving chronic warfarin therapy. J Thromb Thrombolysis. 1998;5(3):257-61. [pmid: 10767122].
9 Bordia A, Verma SK, Srivastava KC. Effect of garlic (Allium sativum) on blood lipids, blood sugar, fibrinogen and fibrinolytic activity in patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. Apr. 1998;58(4):257-63. [pmid: 9654398].
10 Budoff MJ, Takasu J, Flores FR, et al. Inhibiting progression of coronary calcification using Aged Garlic Extract in patients receiving statin therapy: a preliminary study. Prev Med. Nov. 2004;39(5):985-91. [pmid: 15475033].
11 Caso G, Kelly P, McNurlan MA, et al. Effect of coenzyme q10 on myopathic symptoms in patients treated with statins. Am J Cardiol. May. 15. 2007;99(10):1409-12. [pmid: 17493470].
12 Chan DC, Watts GF, Mori TA, et al. Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. Eur J Clin Invest. Jun. 2002;32(6):429-36. [pmid: 12059988].
13 d'Arcangues C, Piaggio G, Brache V, et al. Effectiveness and acceptability of vitamin E and low-dose aspirin, alone or in combination, on Norplant-induced prolonged bleeding. Contraception. Dec. 2004;70(6):451-62. [pmid: 15541406].
14 Davidson MH, Stein EA, Bays HE, et al. Efficacy and tolerability of adding prescription omega-3 fatty acids 4 g/d to simvastatin 40 mg/d in hypertriglyceridemic patients: an 8-week, randomized, double-blind, placebo-controlled study. Clin Ther. Jul. 2007;29(7):1354-67. [pmid: 17825687].
15 Davidson MH, Macariola-Coad JR, McDonald AM, et al. Separate and joint effects of marine oil and simvastatin in patients with combined hyperlipidemia. Am J Cardiol. Sep. 15. 1997;80(6):797-8. [pmid: 9315596].
16 De Caterina R, Cipollone F, Filardo FP, et al. Low-density lipoprotein level reduction by the 3-hydroxy-3-methylglutaryl coenzyme-A inhibitor simvastatin is accompanied by a related reduction of F2-isoprostane formation in hypercholesterolemic subjects: no further effect of vitamin E. Circ Cardiovasc Qual Outcomes. Nov. 12. 2002;106(20):2543-9. [pmid: 12427649].
17 Dehmer GJ, Popma JJ, van den Berg EK, et al. Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids. N Engl J Med. Sep. 22. 1988;319(12):733-40. [pmid: 2842680].
18 Desideri G, Croce G, Tucci M, et al. Effects of bezafibrate and simvastatin on endothelial activation and lipid peroxidation in hypercholesterolemia: evidence of different vascular protection by different lipid-lowering treatments. J Clin Endocrinol Metab. Nov. 2003;88(11):5341-7. [pmid: 14602771].
19 Di Spirito M, Morelli G, Doyle RT, et al. Effect of omega-3-acid ethyl esters on steady-state plasma pharmacokinetics of atorvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2939-45. [pmid: 19006470].
20 Duffy SJ, O'Brien RC, New G, et al. Effect of anti-oxidant treatment and cholesterol lowering on resting arterial tone, metabolic vasodilation and endothelial function in the human forearm: a randomized, placebo-controlled study. Clin Exp Pharmacol Physiol. May. 2001;28(5–6):409-18. [pmid: 11380515].
21 Eritsland J, Arnesen H, Gr⊘nseth K, et al. Effect of dietary supplementation with n-3 fatty acids on coronary artery bypass graft patency. Am J Cardiol. Jan. 1. 1996;77(1):31-6. [pmid: 8540453].
22 Ferraro PM, Ferraccioli GF, Gambaro G, et al. Combined treatment with renin-angiotensin system blockers and polyunsaturated fatty acids in proteinuric IgA nephropathy: a randomized controlled trial. Nephrol Dial Transplant. Jan. 2009;24(1):156-60. [pmid: 18685141].
23 Gardner CD, Zehnder JL, Rigby AJ, et al. Effect of Ginkgo biloba (EGb 761) and aspirin on platelet aggregation and platelet function analysis among older adults at risk of cardiovascular disease: a randomized clinical trial. Blood Coagul Fibrinolysis. Dec. 2007;18(8):787-93. [pmid: 17982321].
24 Garg RK, Nag D, Agrawal A. A double blind placebo controlled trial of ginkgo biloba extract in acute cerebral ischaemia. J Assoc Physicians India. Nov. 1995;43(11):760-3. [pmid: 8773035].
25 Glynn RJ, Ridker PM, Goldhaber SZ, et al. Effects of random allocation to vitamin E supplementation on the occurrence of venous thromboembolism: report from the Women's Health Study. Circ Cardiovasc Qual Outcomes. Sep. 25. 2007;116(13):1497-503. [pmid: 17846285].
26 Gosai P, Liu J, Doyle RT, et al. Effect of omega-3-acid ethyl esters on the steady-state plasma pharmacokinetics of rosuvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2947-53. [pmid: 19006471].
27 Govil MK, Agrawal BD, Gupta BK, et al. The role of magnesium in digitalis--induced arrhythmias. J Assoc Physicians India. Dec. 1979;27(12):1059-65. [pmid: 549914].
28 Hajda J, Rentsch KM, Gubler C, et al. Garlic extract induces intestinal P-glycoprotein, but exhibits no effect on intestinal and hepatic CYP3A4 in humans. Eur J Pharm Sci. Dec. 23. 2010;41(5):729-35. [pmid: 20933082].
29 Hansen JB, Lyngmo V, Svensson B, et al. Inhibition of exercise-induced shortening of bleeding time by fish oil in familial hypercholesterolemia (type IIa). Arterioscler Thromb. Jan. 1993;13(1):98-104. [pmid: 8422345].
30 Howe PR, Lungershausen YK, Cobiac L, et al. Effect of sodium restriction and fish oil supplementation on BP and thrombotic risk factors in patients treated with ACE inhibitors. J Hum Hypertens. Jan. 1994;8(1):43-9. [pmid: 8151606].
31 Isley WL, Miles JM, Harris WS. Pilot study of combined therapy with omega-3 fatty acids and niacin in atherogenic dyslipidemia. J Clin Lipidol. 2007;1(3):211-7. [pmid: 21291683].
32 Jiang X, Williams KM, Liauw WS, et al. Effect of ginkgo and ginger on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects. Br J Clin Pharmacol. Apr. 2005;59(4):425-32. [pmid: 15801937].
33 Jiang X, Williams KM, Liauw WS, et al. Effect of St John's wort and ginseng on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects. [Erratum appears in Br J Clin Pharmacol. 2004 Jul;58(1):102]. Br J Clin Pharmacol. May. 2004;57(5):592-9. [pmid: 15089812].
34 Kaul U, Sanghvi S, Bahl VK, et al. Fish oil supplements for prevention of restenosis after coronary angioplasty. Int J Cardiol. Apr. 1992;35(1):87-93. [pmid: 1563884].
35 Kim BH, Kim KP, Lim KS, et al. Influence of Ginkgo biloba extract on the pharmacodynamic effects and pharmacokinetic properties of ticlopidine: an open-label, randomized, two-period, two-treatment, two-sequence, single-dose crossover study in healthy Korean male volunteers. Clin Ther. Feb. 2010;32(2):380-90. [pmid: 20206795].
36 Lee SH, Ahn YM, Ahn SY, et al. Interaction between warfarin and Panax ginseng in ischemic stroke patients. J Altern Complement Med. Jul. 2008;14(6):715-21. [pmid: 18637764].
37 Liu M, Wallmon A, Wallin R, et al. Effects of stable fish oil and simvastatin on plasma lipoproteins in patients with hyperlipidemia. Nutr Res. 2003;23(8):1027-34.
38 Lungershausen YK, Howe PR. Improved detection of a blood pressure response to dietary intervention with 24-hour ambulatory monitoring. Am J Hypertens. Dec. 1994;7(12):1115-7. [pmid: 7702808].
39 Mabuchi H, Nohara A, Kobayashi J, et al. Effects of CoQ10 supplementation on plasma lipoprotein lipid, CoQ10 and liver and muscle enzyme levels in hypercholesterolemic patients treated with atorvastatin: a randomized double-blind study. Atherosclerosis. Dec. 2007;195(2):e182-e189. [pmid: 17681347].
40 Macan H, Uykimpang R, Alconcel M, et al. Aged garlic extract may be safe for patients on warfarin therapy. J Nutr. Mar. 2006;136(3 Suppl):793S-5S. [pmid: 16484565].
41 Maki KC, McKenney JM, Reeves MS, et al. Effects of adding prescription omega-3 acid ethyl esters to simvastatin (20 mg/day) on lipids and lipoprotein particles in men and women with mixed dyslipidemia. [Erratum appears in Am J Cardiol. 2008 Nov 15;102(10):1425]. Am J Cardiol. Aug. 15. 2008;102(4):429-33. [pmid: 18678300].
42 Manuel YK, Vinckx M, Vertommen J, et al. Impact of Vitamin E supplementation on lipoprotein peroxidation and composition in Type 1 diabetic patients treated with Atorvastatin. Atherosclerosis. Aug. 2004;175(2):369-76. [pmid: 15262194].
43 Mauro VF, Mauro LS, Kleshinski JF, et al. Impact of ginkgo biloba on the pharmacokinetics of digoxin. Am J Ther. Jul. 2003;10(4):247-51. [pmid: 12845387].
44 McDowell IF, Brennan GM, McEneny J, et al. The effect of probucol and vitamin E treatment on the oxidation of low-density lipoprotein and forearm vascular responses in humans. Eur J Clin Invest. Nov. 1994;24(11):759-65. [pmid: 7890014].
45 McKenney JM, Swearingen D, Di SM, et al. Study of the pharmacokinetic interaction between simvastatin and prescription omega-3-acid ethyl esters. J Clin Pharmacol. Jul. 2006;46(7):785-91. [pmid: 16809804].
46 Meyer BJ, Hammervold T, Rustan AC, et al. Dose-dependent effects of docosahexaenoic acid supplementation on blood lipids in statin-treated hyperlipidaemic subjects. Lipids. Mar. 2007;42(2):109-15. [pmid: 17393216].
47 Micheletta F, Natoli S, Misuraca M, et al. Vitamin E supplementation in patients with carotid atherosclerosis: reversal of altered oxidative stress status in plasma but not in plaque. Arterioscler Thromb Vasc Biol. Jan. 2004;24(1):136-40. [pmid: 14592846].
48 Miyamoto S, Kawano H, Takazoe K, et al. Vitamin E improves fibrinolytic activity in patients with coronary spastic angina. Thromb Res. 2004;113(6):345-51. [pmid: 15226088].
49 Mohammed Abdul MI, Jiang X, Williams KM, et al. Pharmacodynamic interaction of warfarin with cranberry but not with garlic in healthy subjects. Br J Pharmacol. Aug. 2008;154(8):1691-700. [pmid: 18516070].
50 Motoyama T, Kawano H, Kugiyama K, et al. Vitamin E administration improves impairment of endothelium-dependent vasodilation in patients with coronary spastic angina. J Am Coll Cardiol. Nov. 15. 1998;32(6):1672-9. [pmid: 9822095].
51 Mueller BA, Talbert RL, Tegeler CH, et al. The bleeding time effects of a single dose of aspirin in subjects receiving omega-3 fatty acid dietary supplementation. J Clin Pharmacol. Feb. 1991;31(2):185-90. [pmid: 2010565].
52 Napoli C, Leccese M, Palumbo G, et al. Effects of vitamin E and HMG-CoA reductase inhibition on cholesteryl ester transfer protein and lecithin-cholesterol acyltransferase in hypercholesterolemia. Coron Artery Dis. 1998;9(5):257-64. [pmid: 9710685].
53 Neil HA, Ceglarek U, Thiery J, et al. Impact of atorvastatin and omega-3 ethyl esters 90 on plasma plant sterol concentrations and cholesterol synthesis in type 2 diabetes: a randomised placebo controlled factorial trial. Atherosclerosis. Dec. 2010;213(2):512-7. [pmid: 21036355].
54 Nordøy A, Bonaa KH, Sandset PM, et al. Effect of omega-3 fatty acids and simvastatin on hemostatic risk factors and postprandial hyperlipemia in patients with combined hyperlipemia. Arterioscler Thromb Vasc Biol. Jan. 2000;20(1):259-65. [pmid: 10634827].
55 Nordøy A, Svensson B, Hansen JB. Atorvastatin and omega-3 fatty acids protect against activation of the coagulation system in patients with combined hyperlipemia. J Thromb Haemost. 2003;1(4):690-7. [pmid: 12871402].
56 Paolisso G, Gambardella A, Giugliano D, et al. Chronic intake of pharmacological doses of vitamin E might be useful in the therapy of elderly patients with coronary heart disease. Am J Clin Nutr. Apr. 1995;61(4):848-52. [pmid: 7702030].
57 Paolisso G, Di Maro G, Cozzolino D, et al. Chronic magnesium administration enhances oxidative glucose metabolism in thiazide treated hypertensive patients. Am J Hypertens. Oct. 1992;5(10):681-6. [pmid: 1418829].
58 Playford DA, Watts GF, Croft KD, et al. Combined effect of coenzyme Q10 and fenofibrate on forearm microcirculatory function in type 2 diabetes. Atherosclerosis. May. 2003;168(1):169-79. [pmid: 12732401].
59 Reyes AJ, Leary WP, Acosta-Barrios TN, et al. Magnesium supplementation in hypertension treated with hydrochlorothiazide. Curr Ther Res, Clin Exp. 1984;36(2):332-40.
60 Roth EM, Bays HE, Forker AD, et al. Prescription omega-3 fatty acid as an adjunct to fenofibrate therapy in hypertriglyceridemic subjects. J Cardiovasc Pharmacol. Sep. 2009;54(3):196-203. [pmid: 19597368].
61 Sconce E, Avery P, Wynne H, et al. Vitamin K supplementation can improve stability of anticoagulation for patients with unexplained variability in response to warfarin. Blood. Mar. 15. 2007;109(6):2419-23. [pmid: 17110451].
62 Steiner M, Glantz M, Lekos A. Vitamin E plus aspirin compared with aspirin alone in patients with transient ischemic attacks. Am J Clin Nutr. Dec. 1995;62(6 Suppl):1381S-4S. [pmid: 7495235].
63 Sutken E, Inal M, Ozdemir F. Effects of vitamin E and gemfibrozil on lipid profiles, lipid peroxidation and antioxidant status in the elderly and young hyperlipidemic subjects. Saudi Med J. Apr. 2006;27(4):453-9. [pmid: 16598319].
64 Svaneborg N, Kristensen SD, Hansen LM, et al. The acute and short-time effect of supplementation with the combination of n-3 fatty acids and acetylsalicylic acid on platelet function and plasma lipids. Thromb Res. Feb. 15. 2002;105(4):311-6. [pmid: 12031825].
65 Tankanow R, Tamer HR, Streetman DS, et al. Interaction study between digoxin and a preparation of hawthorn (Crataegus oxyacantha). J Clin Pharmacol. Jun. 2003;43(6):637-42. [pmid: 12817526].
66 Watson PS, Scalia GM, Galbraith A, et al. Lack of effect of coenzyme Q on left ventricular function in patients with congestive heart failure. J Am Coll Cardiol. 1999;33(6):1549-52. [pmid: 10334422].
67 Wirell MP, Wester PO, Stegmayr BG. Nutritional dose of magnesium in hypertensive patients on beta blockers lowers systolic blood pressure: a double-blind, cross-over study. J Intern Med. Aug. 1994;236(2):189-95. [pmid: 7913949].
68 Wolf HR. Does Ginkgo biloba special extract EGb 761 provide additional effects on coagulation and bleeding when added to acetylsalicylic acid 500 mg daily?. Drugs in R & D. 2006;7(3):163-72. [pmid: 16752942].
69 Yamamoto H, Yoshimura H, Noma M, et al. Improvement of coronary vasomotion with eicosapentaenoic acid does not inhibit acetylcholine-induced coronary vasospasm in patients with variant angina. [Erratum appears in Jpn Circ J 1995 Nov; 59, 11:773–4]. Jpn Circ J. Sep. 1995;59(9):608-16. [pmid: 7500544].
70 Young JM, Florkowski CM, Molyneux SL, et al. Effect of coenzyme Q(10) supplementation on simvastatin-induced myalgia. Am J Cardiol. Nov. 1. 2007;100(9):1400-3. [pmid: 17950797].
71 Yuan CS, Wei G, Dey L, et al. Brief communication: American ginseng reduces warfarin's effect in healthy patients: a randomized, controlled Trial. Ann Intern Med. Jul. 6. 2004;141(1):23-7. [pmid: 15238367].
72 Whitlock RP, Crowther MA, Warkentin TE, et al. Warfarin cessation before cardiopulmonary bypass: lessons learned from a randomized controlled trial of oral vitamin K. Ann Thorac Surg. Jul. 2007;84(1):103-8. [pmid: 17588394].