# Excluded Studies

Appendix D lists all of the studies that were excluded from this review, categorized by reason for exclusion and alphabetized.

## Not Relevant Intervention(s)/Exposure(s) and Comparator(s)

Eligibility: Relevant dietary supplement VS. no dietary supplement (e.g. no treatment or placebo) OR Relevant dietary supplement VS. other relevant dietary supplement.

Clofibrate and niacin in coronary heart disease. J Am Med Assoc. Jan. 27. 1975;231(4):360-81. [pmid: 1088963].
Drugs for hypertension. Med Lett Drugs Ther. Mar. 11. 1977;19(5):21-4. [pmid: 840157].
Systematic overview of controlled trials (meta-analysis) helps clarify treatment effects. Drug Ther Bull. Mar. 30. 1992;30(7):25-7. [pmid: 1534294].
Lowering blood homocysteine with folic acid based supplements: meta-analysis of randomised trials Homocysteine Lowering Trialists' Collaboration. BMJ. Mar. 21. 1998;316(7135):894-8. [pmid: 9569395].
Cholesterol-lowering margarines. Med Lett Drugs Ther. Jun. 18. 1999;41(1055):56-8. [pmid: 10436768].
Dietary supplements: (2) green tea. Pharmaceutical Journal. 2001;267(7177):823. Date of Publication: 08 Dec 2001 2001;(7177):823.
HMG-CoA reductase inhibitors (STATINS). Med Lett Drugs Ther. 2001;43(1105):44-8.
A close look at coenzyme Q10 and policosanol. Do these supplements live up to their claims for improving heart health?. Harv Heart Lett. Dec. 2002;13(4):6. [pmid: 12499156].
Monograph. Angelica sinensis. Altern Med Rev. Dec. 2004;9(4):429-33. [pmid: 15656714].
Vitamins, minerals, supplements and dietary approaches. Focus on Alternative and Complementary Therapies. 2005;10(3):227-32.
Omega-3 polyunsaturated fatty acids (Omacor) for hypertriglyceridemia. Med Lett Drugs Ther. Nov. 7. 2005;47(1221):91. [pmid: 16267495].
More than a pleasant odor. [German]. Praxis (Bern 1994). Aug. 10. 2005;94(32):1236. [pmid: 16128212].
New evidence of uselessness of intravenous glucose-insulin-potassium infusion in patients with ST-segment elevation myocardial infarction: results of meta-analysis of CREATE-ECLA and OASIS-6 trials. [Review] [8 refs] [Russian]. Kardiologiia. 2008;48(1):76. [pmid: 18261001].
3 steps to stroke prevention and stroke recovery. Drink tea, take statins, and change negative lifestyle habits--even just one--to aid stroke risk reduction and recovery. Duke Med Health News. May. 2009;15(5):4-5. [pmid: 19746513].
Docosahexaenoic acid (DHA). Alternative Medicine Review. 2009;14(4):391-399. Date of Publication: December 2009 2009;(4):391–9. [pmid: 20030466].
Micronutrients: Tap the full potential!. [German]. Dtsch Apoth Ztg. 2010;150(12):86-7.
Abebe W. Herbal supplements may require modifications of dental treatment. Dent Today. Jan. 2009;28(1):136-7. [pmid: 19323340].
Accinni R, Rosina M, Bamonti F, et al. Effects of combined dietary supplementation on oxidative and inflammatory status in dyslipidemic subjects. Nutr Metab Cardiovasc Dis. Mar. 2006;16(2):121-7. [pmid: 16487912].
Adeghate E, Kalasz H, Veress G, et al. Medicinal chemistry of drugs used in diabetic cardiomyopathy. [Review] [234 refs]. Curr Med Chem. 2010;17(6):517-51. [pmid: 20015035].
Agarwal OP. Prevention of atheromatous heart disease. Angiology. Aug. 1985;36(8):485-92. [pmid: 2864002].
Ageno W, Crowther M, Steidl L, et al. Low dose oral vitamin K to reverse acenocoumarol-induced coagulopathy: a randomized controlled trial. Thromb Haemost. Jul. 2002;88(1):48-51. [pmid: 12152676].
Ageno W, Garcia D, Silingardi M, et al. A randomized trial comparing 1 mg of oral vitamin K with no treatment in the management of warfarin-associated coagulopathy in patients with mechanical heart valves. J Am Coll Cardiol. Aug. 16. 2005;46(4):732-3. [pmid: 16098445].
Aggarwal A. Interactions of herbal remedies with prescription cardiovascular medications. Coron Artery Dis. 2001;12(7):581-4. [pmid: 11714999].
Agler AH, Kurth T, Gaziano JM, et al. Randomised vitamin E supplementation and risk of chronic lung disease in the Women's Health Study. Thorax. Apr. 2011;66(4):320-5. [pmid: 21257986].
Agouridis AP, Filippatos TD, Tsimihodimos V, et al. Combinations of ezetimibe with nonstatin drug regimens affecting lipid metabolism. [Review]. Expert Rev Cardiovasc Ther. Mar. 2011;9(3):355-66. [pmid: 21438815].
Ahmed W, Khan N, Glueck CJ, et al. Low serum 25 (OH) vitamin D levels (<32 ng/mL) are associated with reversible myositis-myalgia in statin-treated patients. Transl Res. Jan. 2009;153(1):11-6. [pmid: 19100953].
AIM-HIGH I. The role of niacin in raising high-density lipoprotein cholesterol to reduce cardiovascular events in patients with atherosclerotic cardiovascular disease and optimally treated low-density lipoprotein cholesterol: baseline characteristics of study participants. The Atherothrombosis Intervention in Metabolic syndrome with low HDL/high triglycerides: impact on Global Health outcomes (AIM-HIGH) trial. Am Heart J. Mar. 2011;161(3):538-43. [pmid: 21392609].
Airan-Javia SL, Wolf RL, Wolfe ML, et al. Atheroprotective lipoprotein effects of a niacin-simvastatin combination compared to low- and high-dose simvastatin monotherapy. Am Heart J. Apr. 2009;157(4):687-8. [pmid: 19332196].
Alberio L. Oral anticoagulation with vitamin K antagonists. [Review] [9 refs] [German]. Ther Umsch. Jan. 2003;60(1):5-9. [pmid: 12638470].
Alderman JD, Pasternak RC, Sacks FM, et al. Effect of a modified, well-tolerated niacin regimen on serum total cholesterol, high density lipoprotein cholesterol and the cholesterol to high density lipoprotein ratio. Am J Cardiol. Oct. 1. 1989;64(12):725-9. [pmid: 2801522].
Allard ML, Jeejeebhoy KN, Sole MJ. Th 1f40 e management of conditioned nutritional requirements in heart failure. [Review] [77 refs]. Heart Fail Rev. Mar. 2006;11(1):75-82. [pmid: 16819580].
Almendingen K, Lia A. Presence of plant sterols in the diet and the hypocholesterolemic effects of plant sterols. [Review] [45 refs] [Norwegian]. Tidsskr Nor Laegeforen. Sep. 20. 2000;120(22):2661-5. [pmid: 11077512].
Aloia JF, Li-Ng M, Pollack S. Statins and vitamin D. Am J Cardiol. Oct. 15. 2007;100(8):1329. [pmid: 17920383].
Alsheikh-Ali AA, Karas RH. Safety of lovastatin/extended release niacin compared with lovastatin alone, atorvastatin alone, pravastatin alone, and simvastatin alone (from the United States Food and Drug Administration adverse event reporting system). Am J Cardiol. Feb. 1. 2007;99(3):379-81. [pmid: 17261402].
Alter HJ, Koepsell TD, Hilty WM. Intravenous magnesium as an adjuvant in acute bronchospasm: a meta-analysis. Ann Emerg Med. Sep. 2000;36(3):191-7. [pmid: 10969219].
Amery A, Berthaux P, Birkenhäger W, et al. Antihypertensive therapy in patients above age 60 years (Fourth Interim report of the European Working Party on High Blood pressure in Elderly: EWPHE). Clin Sci Mol Med Suppl. Dec. 1978;4:263s-70s. [pmid: 365433].
Amsterdam EA. Benefit on atherosclerosis of adding niacin in patients with low HDL-cholesterol taking a statin. Prev Cardiol. 2005;8(2):130. [pmid: 15860992].
Anderson GH Jr, Howland T, Domescek R, et al. Effect of sodium balance and calcium channel blocking drugs on blood pressure responses. Hypertension. Sep. 1987;10(3):239-48. [pmid: 3623678].
Anderson JW, Major AW. Pulses and lipaemia, short- and long-term effect: potential in the prevention of cardiovascular disease. Br J Nutr. Dec. Suppl 3. 2002;88:S263-271. [pmid: 12498626].
Andersson SE, Edvinsson ML, Edvinsson L. Reduction of homocysteine in elderly with heart failure improved vascular function and blood pressure control but did not affect inflammatory activity. Basic Clin Pharmacol Toxicol. Nov. 2005;97(5):306-10. [pmid: 16236143].
Antalóczy Z. Drug therapy of arrhythmia. Die Medizinische Welt. 1971;44:1768-71. [pmid: 5125846].
Appleton MP, Kuehl TJ, Raebel MA, et al. Magnesium sulfate versus phenytoin for seizure prophylaxis in pregnancy-induced hypertension. Am J Obstet Gynecol. Oct. 1991;165(4 Pt 1):907-13. [pmid: 1951552].
Apstein CS, Opie LH. Glucose-insulin-potassium (GIK) for acute myocardial infarction: a negative study with a positive value. [Review] [38 refs]. Cardiovasc Drugs Ther. May. 1999;13(3):185-9. [pmid: 10439880].
Arana V, Paz Y, González A, et al. Healing of diabetic foot ulcers in L-arginine-treated patients. Biomed Pharmacother. Dec. 2004;58(10):588-97. [pmid: 15589068].
Arar C, Colak A, Alagol A, et al. The use of esmolol and magnesium to prevent haemodynamic responses to extubation after coronary artery grafting. Eur J Anaesthesiol. Oct. 2007;24(10):826-31. [pmid: 17583595].
Armayor GM, Lopez LM. Lisinopril: a new angiotensin-converting enzyme inhibitor. [Review] [63 refs][Erratum appears in Drug Intell Clin Pharm 1988 Nov;22(11):920]. Drug Intell Clin Pharm. May. 1988;22(5):365-72. [pmid: 2839326].
Armstrong EP, Zachry WM III, Malone DC. Cost-effectiveness analysis of simvastatin and lovastatin/extended-release niacin to achieve LDL and HDL goal using NHANES data. J Manage Care Pharm. May. 2004;10(3):251-8. [pmid: 15228376].
Arnold JMO, Liu P, Demers C, et al. Canadian Cardiovascular Society consensus conference recommendations on heart failure 2006: Diagnosis and management. Can J Cardiol. 2006;22(1):23-45. [pmid: 16450016].
Athyros VG, Tziomalos K, Mikhailidis DP, et al. Do we need a statin-nicotinic acid-aspirin mini-polypill to treat combined hyperlipidaemia?. [Review] [104 refs]. Expert Opin Pharmacother. Oct. 2007;8(14):2267-77. [pmid: 17927482].
Authors. Norm&#x00E9, nL, Dutta P, et al. Soy sterol esters and beta-sitostanol ester as inhibitors of cholesterol absorption in human small bowel. Am J Clin Nutr. Apr. 2000;71(4):908-13. [pmid: 10731496].
Authors. Rehulkov&#x00E1 O. Interactions of warfarin. [Review] [270 refs]. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Dec. 2001;145(2):27-38. [pmid: 12426769].
Avogaro P, Bittolo-Bon G, Pais M, et al. Effect of a new niacin derivative (nicotinic hexaester of D-glucitol) on type IIA, IIB and IV hyperlipoproteinemia in man. Pharmacol Res Commun. Jun. 1977;9(6):599-606. [pmid: 197548].
Azadbakht L, Kimiagar M, Mehrabi Y, et al. Soy consumption, markers of inflammation, and endothelial function: a cross-over study in postmenopausal women with the metabolic syndrome. Diabetes Care. Apr. 2007;30(4):967-73. [pmid: 17392557].
Baker RI, Coughlin PB, Gallus AS, et al. Warfarin reversal: consensus guidelines, on behalf of the Australasian Society of Thrombosis and Haemostasis. [Review] [38 refs][Erratum appears in Med J Aust. 2005 Jan 3;182(1):48]. Med J Aust. Nov. 1. 2004;181(9):492-7. [pmid: 15516194].
Balayssac S, Trefi S, Gilard V, et al. 2D and 3D DOSY 1H NMR, a useful tool for analysis of complex mixtures: application to herbal drugs or dietary supplements for erectile dysfunction. J Pharm Biomed Anal. Nov. 1. 2009;50(4):602-12. [pmid: 19108978].
Ballantyne CM, Davidson MH, McKenney J, et al. Comparison of the safety and efficacy of a combination tablet of niacin extended release and simvastatin vs simvastatin monotherapy in patients with increased non-HDL cholesterol (from the SEACOAST I study). Am J Cardiol. May. 15. 2008;101(10):1428-36. [pmid: 18471454].
Barakat MR, Metelitsina TI, DuPont JC, et al. Effect of niacin on retinal vascular diameter in patients with age-related macular degeneration. Curr Eye Res. Jul. 2006;31(7–8):629-34. [pmid: 16877271].
Barragán-Rodríguez L, Rodríguez-Morán M, Guerrero-Romero F. Efficacy and safety of oral magnesium supplementation in the treatment of depression in the elderly with type 2 diabetes: a randomized, equivalent trial. Magnesium research : official organ of the International Society for the Development of Research on Magnesium. 2008;21(4):218-23. [pmid: 19271419].
Basile JN. ACE inhibitor-associated cough lessened with iron supplementation. J Clin Hypertens (Greenwich). Jan. 2002;4(1):49-50. [pmid: 11821639].
Basu TK. Drug-vitamin interaction. [Review] [66 refs]. Int J Vitam Nutr Res Suppl. 1985;27:247-58. [pmid: 3926698].
Baxter GF, Sumeray MS, Walker JM. Infarct size and magnesium: insights into LIMIT-2 and ISIS-4 from experimental studies. La 1f40 ncet. Nov. 23. 1996;348(9039):1424-6. [pmid: 8937284].
Bays HE, McGovern ME. Once. -daily niacin extended release/lovastatin combination tablet has more favorable effects on lipoprotein particle size and subclass distribution than atorvastatin and simvastatin. Prev Cardiol. 2003;6(4):179-88. [pmid: 14605511].
Bays HE. Extended-release niacin/lovastatin: the first combination product for dyslipidemia. [Review] [84 refs]. Expert Rev Cardiovasc Ther. Jul. 2004;2(4):485-501. [pmid: 15225109].
Bays HE, Ballantyne C. What's the deal with niacin development: is laropiprant add-on therapy a winning strategy to beat a straight flush?. [Review] [45 refs]. Curr Opin Lipidol. Dec. 2009;20(6):467-76. [pmid: 19779335].
Bays HE, Maccubbin D, Meehan AG, et al. Blood pressure-lowering effects of extended-release niacin alone and extended-release niacin/laropiprant combination: a post hoc analysis of a 24-week, placebo-controlled trial in dyslipidemic patients. Clin Ther. Jan. 2009;31(1):115-22. [pmid: 19243712].
Bays HE, Maki KC, McKenney J, et al. Long-term up to 24-month efficacy and safety of concomitant prescription omega-3-acid ethyl esters and simvastatin in hypertriglyceridemic patients. Curr Med Res Opin. Apr. 2010;26(4):907-15. [pmid: 20156032].
Beaumont V, Buxtorf JC, Jacotot B, et al. Comparative study of several hypolipidemic agents related to clofibrate. Atherosclerosis. Sep. 1974;20(2):141-53. [pmid: 4369878].
Beg M, Singhal KC, Afzaal S. A study of effect of guggulsterone on hyperlipidemia of secondary glomerulopathy. Indian J Physiol Pharmacol. Jul. 1996;40(3):237-40. [pmid: 8950139].
Belcaro G, Cesarone MR, Dugall M, et al. Investigation of Pycnogenol[REGISTERED] in combination with coenzymeQ10 in heart failure patients (NYHA II/III). Panminerva Med. Jun. 2010;52(2 Suppl 1):21-5. [pmid: 20657530].
Belfort M, Allred J, Dildy G. Magnesium sulfate decreases cerebral perfusion pressure in preeclampsia. HYPERTENS. 2008;27(4):315-27. [pmid: 19003633].
Berndt H. Modern thiamine therapy. [Review] [161 refs] [German]. Ther Ggw. Dec. 1967;106(12):1543-6. [pmid: 4915826].
Birjmohun RS, Kastelein JJ, Poldermans D, et al. Safety and tolerability of prolonged-release nicotinic acid in statin-treated patients. Curr Med Res Opin. Jul. 2007;23(7):1707-13. [pmid: 17588301].
Black C, Paterson KR. New antiplatelet agents: Ticlopidine and clopidogrel. Antiplatelet therapy but at what cost?. Adverse Drug React Toxicol Rev. 2001;20(4):277-303. [pmid: 11770173].
Blankenhorn DH, Johnson RL, Nessim SA, et al. The Cholesterol Lowering Atherosclerosis Study (CLAS): design, methods, and baseline results. Control Clin Trials. Dec. 1987;8(4):356-87. [pmid: 3327654].
Blankenhorn DH, Azen SP, Crawford DW, et al. Effects of colestipol-niacin therapy on human femoral atherosclerosis. Circ Cardiovasc Qual Outcomes. Feb. 1991;83(2):438-47. [pmid: 1991366].
Bliznakov EG. Lipid-lowering drugs (statins), cholesterol, and coenzyme Q10. The Baycol case--a modern Pandora's box. Biomed Pharmacother. Feb. 2002;56(1):56-9. [pmid: 11905511].
Bodnar L, Wcislo G, Gasowska-Bodnar A, et al. Renal protection with magnesium subcarbonate and magnesium sulphate in patients with epithelial ovarian cancer after cisplatin and paclitaxel chemotherapy: a randomised phase II study. Eur J Cancer. Nov. 2008;44(17):2608-14. [pmid: 18796350].
Boesgaard S, Pedersen J. Reversal of tolerance to nitroglycerin: Dose-dependent effect of N-acetylcysteine and glutathione supplementation. In Fourth International Symposium on Cardiovascular Pharmacotherapy. 1991 Apr 21. 1991.
Booth SL, Charnley JM, Sadowski JA, et al. Dietary vitamin K1 and stability of oral anticoagulation: proposal of a diet with constant vitamin K1 content. [Review] [63 refs]. Thromb Haemost. Mar. 1997;77(3):504-9. [pmid: 9066002].
Borodin EA, Menshikova IG, Dorovskikh VA, et al. Effects of two-month consumption of 30 g a day of soy protein isolate or skimmed curd protein on blood lipid concentration in Russian adults with hyperlipidemia. J Nutr Sci Vitaminol (Tokyo). Dec. 2009;55(6):492-7. [pmid: 20086319].
Bothe W, Olschewski M, Beyersdorf F, et al. Glucose-insulin-potassium in cardiac surgery: a meta-analysis. Ann Thorac Surg. Nov. 2004;78(5):1650-7. [pmid: 15511450].
Boucher BJ. Endothelial dysfunctionl has vitamin D a role?. Diabet Med. Jan. 2011;28(1):125-6. [pmid: 21166857].
Boushey CJ, Beresford SA, Omenn GS, et al. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA. Oct. 4. 1995;274(13):1049-57. [pmid: 7563456].
Boxer RS, Kenny AM, Cheruvu VK, et al. Serum 25-hydroxyvitamin D concentration is associated with functional capacity in older adults with heart failure. Am Heart J. Nov. 2010;160(5):893-9. [pmid: 21095277].
Bricker LA. A clinical approach to the hyperlipidemias. [Review] [69 refs]. Med Clin North Am. Mar. 1971;55(2):403-19. [pmid: 4323548].
Britt BA. Diltiazem. [Review] [128 refs]. Can Anaesth Soc J. Jan. 1985;32(1):30-44. [pmid: 3882198].
Broomé A, Cederlund J, Eklöf B. The effect of nicotinic acid on muscle blood flow in intermittent claudication measured with xenon-133 clearance method. Scand J Clin Lab Invest Suppl. 1967;99:233-40. [pmid: 4862835].
Brown BG. Effect of lovastatin or niacin combined with colestipol and regression of coronary atherosclerosis. Eur Heart J. Jul. Suppl B. 1992;13:17-20. [pmid: 1644095].
Brownley KA, Hurwitz BE, Schneiderman N. Ethnic variations in the pharmacological and nonpharmacological treatment of hypertension: biopsychosocial perspective. [Review] [211 refs]. Hum Biol. Aug. 1999;71(4):607-39. [pmid: 10453104].
Bruckert E, Labreuche J, Amarenco P. Meta-analysis of the effect of nicotinic acid alone or in combination on cardiovascular events and atherosclerosis. Atherosclerosis. Jun. 2010;210(2):353-61. [pmid: 20079494].
Burgess E, Lewanczuk R, Bolli P, et al. Lifestyle modifications to prevent and control hypertension. 6. Recommendations on potassium, magnesium and calcium. Canadian Hypertension Society, Canadian Coalition for High Blood Pressure Prevention and Control, Laboratory Centre for Disease Control at Health Canada, Heart and Stroke Foundation of Canada. CMAJ. May. 4. 1999;160(9 Suppl):S35-45. [pmid: 10333852].
Burke LP, Lewis LD, Perez RP. Ubiquinone does not rescue acute myeloid leukemia cells from growth inhibition by statins. Leukemia. Jan. 2003;17(1):267-8. [pmid: 12529692].
Butler VP Jr. Assays of digitalis in the blood. [Review] [156 refs]. Prog Cardiovasc Dis. May. 1972;14(6):571-600. [pmid: 4260476].
Campanacci D. Current data on the physiopathological and therapeutic importance of vitamin C. [Italian]. G Clin Med. Jan. 1974;55(1):1-4. [pmid: 4409096].
Campbell AP. Diabetes and dietary supplements. Clinical Diabetes. 2010;28(1):35-39. Date of Publication: 2010 2010;(1):35–9.
Campese VM. Management of essential hypertension. Whom, when and how to treat. [Review] [55 refs]. Contrib Nephrol. 1987;54:38-53. [pmid: 3552436].
Canter PH, Ernst E. Herbal supplement use by persons aged over 50 years in Britain: Frequently used herbs, concomitant use of herbs, nutritional supplements and prescription drugs, rate of informing doctors and potential for negative interactions. Drugs and Aging. 2004;21(9):597-605. Date of Publication: 2004 2004;(9):597–605. [pmid: 15260514].
Caputo M, Bryan AJ, Calafiore AM, et al. Intermittent antegrade hyperkalaemic warm blood cardioplegia supplemented with magnesium prevents myocardial substrate derangement in patients undergoing coronary artery bypass surgery. Eur J Cardiothorac Surg. Dec. 1998;14(6):596-601. [pmid: 9879871].
Capuzzi DM, Morgan JM, Carey CM, et al. Rosuvastatin alone or with extended-release niacin: a new therapeutic option for patients with combined hyperlipidemia. Prev Cardiol. 2004;7(4):176-81. [pmid: 15539964].
Carruthers-Czyzewski P. GERD in older adults. Canadian Pharmaceutical Journal. 1999;132(2):28-32. Date of Publication: 1999 1999;(2):28–32.
Cashin-Hemphill L, Mack WJ, Pogoda JM, et al. Beneficial effects of colestipol-niacin on coronary atherosclerosis. A 4-year follow-up. J Am Med Assoc. Dec. 1990;264(23):3013-7. [pmid: 2243429].
Casscells W. Magnesium and myocardial infarction. La 1f40 ncet. Apr. 2. 1994;343(8901):807-9. [pmid: 7908073].
Castano G, Arruzazabala ML, Fernandez L, et al. Effects of combination treatment with policosanol and omega-3 fatty acids on platelet aggregation: A randomized, double-blind clinical study. Current Therapeutic Research Clinical and Experimental. 2006;67(3):174-92.
Castaño G, MáS R, Fernández L, et al. A comparison of the effects of D-003 and policosanol (5 and 10 mg/day) in patients with type II hypercholesterolemia: a randomized, double-blinded study. Drugs under experimental and clinical research. 2005;31(Suppl):31-44. [pmid: 16444910].
Castaño G, Fernández L, Mas R, et al. Effects of addition of policosanol to omega-3 fatty acid therapy on the lipid profile of patients with type II hypercholesterolaemia. Drugs in R&D. 2005;6(4):207-19.
Cavallari LH, Aston JL, Momary KM, et al. Predictors of unstable anticoagulation in African Americans. J Thromb Thrombolysis. May. 2009;27(4):430-7. [pmid: 18563532].
Cazenave JP, Wiesel ML, Hemmendinger S. Current treatment for thrombotic diseases. [Review] [141 refs]. Agents Actions Suppl. 1984;15:24-49. [pmid: 6091424].
Cefali EA, Simmons PD, Stanek EJ, et al. Aspirin reduces cutaneous flushing after administration of an optimized extended-release niacin formulation. Int J Clin Pharmacol Ther. Feb. 2007;45(2):78-88. [pmid: 17323787].
Ceriello A, Piconi L, Esposito K, et al. Telmisartan shows an equivalent effect of vitamin C in further improving endothelial dysfunction after glycemia normalization in type 1 diabetes. Diabetes Care. Jul. 2007;30(7):1694-8. [pmid: 17456844].
Chainuvati S, Nafziger AN, Leeder JS, et al. Combined phenotypic assessment of cytochrome p450 1A2, 2C9, 2C19, 2D6, and 3A, N-acetyltransferase-2, and xanthine oxidase activities with the "Cooperstown 5+1 cocktail". Clin Pharmacol Ther. Nov. 2003;74(5):437-47. [pmid: 14586384].
Chakrabarti S, Freedman JE. Review: Nutriceuticals as antithrombotic agents. [Review]. Cardiovasc Ther. Aug. 2010;28(4):227-35. [pmid: 20553290].
Chamiec T, Herbaczynska-Cedro K, Ceremuzynski L. Effects of antioxidant vitamins C and E on signal-averaged electrocardiogram in acute myocardial infarction. Am J Cardiol. Feb. 1. 1996;77(4):237-41. [pmid: 8607400].
Chan DC, Watts GF, Barrett PH, et al. Mechanism of action of a 3-hydroxy-3-methylglutaryl coenzyme a reductase inhibitor on apolipoprotein B-100 kinetics in visceral obesity. J Clin Endocrinol Metab. May. 2002;87(5):2283-9. [pmid: 11994377].
Chan DC, Watts GF. Dyslipidemia in the metabolic syndrome. Journal of Drug Evaluation. 2004;2(1):3-34. Date of Publication: 2004 2004;(1):3–34.
Chan MT, Choi KC, Wong GK, et al. Interaction between magnesium sulfate and acetylsalicylic acid in the MASH trial. Stroke. May. 2007;38(5):e14. [pmid: 17363719].
Chan Y-M, Merkens LS, Connor WE, et al. Effects of dietary cholesterol and simvastatin on cholesterol synthesis in smith-lemli-opitz syndrome. Pediatric Research. 2009;65(6):681-685. Date of Publication: June 2009 2009;(6):681–5. [pmid: 19430384].
Chapidze G, Kapanadze S, Dolidze N, et al. Prevention of coronary atherosclerosis by the use of combination therapy with antioxidant coenzyme Q10 and statins. Georgian Med. Jan. News. 2005;(118):20-5. [pmid: 15821319].
Charland SL, Malone DC. Prediction of cardiovascular event risk reduction from lipid changes associated with high potency dyslipidemia therapy. Curr Med Res Opin. Feb. 2010;26(2):365-75. [pmid: 19995326].
Charman RC, Matthews LB, Braeuler C. Nicotinic acid in the treatment of hypercholesterolemia. A long term study. Angiology. Jan. 1972;23(1):29-35. [pmid: 5009984].
Chen HC, Hsieh MT. Two-year experience with "San-Huang-Hsieh-Hsin-Tang" in essential hypertension. Am J Chin Med. 1986;14(1–2):51-8. [pmid: 3962916].
Chen J, Wu G, Li S, et al. Shengmai (a traditional Chinese herbal medicine) for heart failure. Cochrane Database Syst Rev. 2007;(4):CD005052. [pmid: 17943836].
Chen KJ. The therapeutic effect of purified coronary heart II tablets on 112 cases of angina pectoris by double blind method. [Chinese]. Chung Hua Hsin Hsueh Kuan Ping Tsa Chih. Jun. 1982;10(2):85-9. [pmid: 6751749].
Cheng TO. Herb digoxin interactions. Int J Cardiol. Jun. 7. 2006;110(1):93. [pmid: 16168502].
Cheng TO. Warfarin interaction with herbal drugs and food. Int J Cardiol. Jun. 25. 2007;119(1):107-8. [pmid: 17023070].
Cheung MC, Wolfbauer G, Kennedy H, et al. Plasma phospholipid transfer protein activity in patients with low HDL and cardiovascular disease treated with simvastatin and niacin. Biochim Biophys Acta. Sep. 28. 2001;1537(2):117-24. [pmid: 11566255].
Chiao TB, Lee AJ. Role of pentoxifylline and vitamin E in attenuation of radiation-induced fibrosis. [Review] [30 refs]. Ann Pharmacother. Mar. 2005;39(3):516-22. [pmid: 15701781].
Christen WG, Glynn RJ, Sperduto RD, et al. Age-Related Cataract in a Randomized Trial of Beta-Carotene in Women. Iovs. 2002;43. ARVO E-Abstract 1520.
Chu K, Evans R, Emerson G, et al. Magnesium sulfate versus placebo for paroxysmal atrial fibrillation: a randomized clinical trial. Acad Emerg Med. Apr. 2009;16(4):295-300. [pmid: 19207134].
Chugh SN, Kumar P, Aggarwal HK, et al. Efficacy of magnesium sulphate in aluminium phosphide poisoning--comparison of two different dose schedules. J Assoc Physicians India. May. 1994;42(5):373-5. [pmid: 7829435].
Cinar V, Polat Y, Mogulkoc R, et al. The effect of magnesium supplementation on glucose and insulin levels of tae-kwan-do sportsmen and sedentary subjects. Pakistan Journal of Pharmaceutical Sciences. Jul. 2008;21(3):237-40. [pmid: 18614418].
Clifton P. Plant sterol and stanols--comparison and contrasts. Sterols versus stanols in cholesterol-lowering: is there a difference?. [Review] [49 refs]. Atheroscler Suppl. Oct. 2002;3(3):5-9. [pmid: 12429167].
Codde JP, Vandongen R, Mori TA, et al. Can the synthesis of platelet-activating factor, a potent vasodilator and pro-aggregatory agent, be altered by dietary marine oils?. Clin Exp Pharmacol Physiol. Mar. 1987;14(3):197-202. [pmid: 2822306].
Colhoun HM. Eicosapentaenoic acid for prevention of major coronary events. La 1f40 ncet. Jul. 21. 2007;370(9583):215-6. [pmid: 17658384].
Conlin PR, Erlinger TP, Bohannon A, et al. The DASH diet enhances the blood pressure response to losartan in hypertensive patients. Am J Hypertens. May. 2003;16(5 Pt 1):337-42. [pmid: 12745193].
Coope J. A trial of treatment of hypertension in the elderly in general practice. Acta Med Scand Suppl. 1983;676:141-50. [pmid: 6362344].
Cooper I. Potassium supplementation during diuretic therapy. Curr Ther Res Clin Exp. Jun. 1975;17(6):555-63. [pmid: 808378].
Corrigan JJ Jr, Marcus FI. Coagulopathy associated with vitamin E ingestion. J Am Med Assoc. Dec. 2. 1974;230(9):1300-1. [pmid: 4479598].
Crane MG, Harris JJ, Johns VJ Jr. Hyporeninemic hypertension. Am J Med. Apr. 1972;52(4):457-66. [pmid: 5017240].
Crippa G, Carrara GC. Role of dietary manipulation and drug-diet interaction in the treatment of hypertension. Progress in Pharmacology and Clinical Pharmacology. 1995;10(2):99-111.
Crouse JR III. New developments in the use of niacin for treatment of hyperlipidemia: new considerations in the use of an old drug. [Review] [47 refs]. Coron Artery Dis. Apr. 1996;7(4):321-6. [pmid: 8853585].
Crowther MA, Julian J, McCarty D, et al. Treatment of warfarin-associated coagulopathy with oral vitamin K: a randomised controlled trial. La 1f40 ncet. Nov. 4. 2000;356(9241):1551-3. [pmid: 11075768].
Crowther MA, Douketis JD, Schnurr T, et al. Oral vitamin K lowers the international normalized ratio more rapidly than subcutaneous vitamin K in the treatment of warfarin-associated coagulopathy. A randomized, controlled trial. [Summary for patients in Ann Intern Med. 2002 Aug 20;137(4):139; PMID: 12186539]. 1f40 Annals of Internal Medicine. Aug. 20. 2002;137(4):251-4. [pmid: 12186515].
Crowther MA, Douketis JD, Schnurr T, et al. Oral vitamin K lowers the international normalized ratio more rapidly than subcutaneous vitamin K in the treatment of warfarin-associated coagulopathy. A randomized, controlled trial. Ann Intern Med. 2002;137(4):251-4. [pmid: 12186515].
Crowther MA, Ageno W, Garcia D, et al. Oral vitamin K versus placebo to correct excessive anticoagulation in patients receiving warfarin: a randomized trial. [Summary for patients in Ann Intern Med. 2009 Mar 3;150(5):125; PMID: 19258552]. Ann Intern Med. Mar. 3. 2009;150(5):293-300. [pmid: 19258557].
Crowther MA, Garcia D, Ageno W, et al. Oral vitamin K effectively treats international normalised ratio (INR) values in excess of 10. Results of a prospective cohort study. Thromb Haemost. Jul. 5. 2010;104(1):118-21. [pmid: 20458438].
Curtis L. Nutritional research and retinopathies. Hong Kong Med J. 2008;14(1):81. [pmid: 18239254].
Cutler JA, Follmann D, Elliott P, et al. An overview of randomized trials of sodium reduction and blood pressure. Hypertension. Jan. 1991;17(1 Suppl):I27-33. [pmid: 1987008].
Dalgård C, Christiansen L, Jonung T, et al. No influence of increased intake of orange and blackcurrant juices and dietary amounts of vitamin E on paraoxonase-1 activity in patients with peripheral arterial disease. Eur J Nutr. 2007;46(6):354-63. [pmid: 17712585].
Dallimore KJ. Response to the article, 'Pellagra in a woman using alternative remedies'. Australas J Dermatol. Aug. 1998;39(3):199. [pmid: 9737054].
Damasceno NR, Perez-Heras A, Serra M, et al. Crossover study of diets enriched with virgin olive oil, walnuts or almonds. Effects on lipids and other cardiovascular risk markers. Nutr Metab Cardiovasc Dis. Jun. Suppl 1. 2011;21:S14-20. [pmid: 21421296].
Dana JB. Reappraisal of digitalis. X. Treatment of digitalis toxicity. J Maine Med Assoc. Oct. 1967;58(10):223. [pmid: 6075610].
Danladi KY, Sotunmbi PT, Eyelade OR. The effects of magnesium sulphate-pretreatment on suxamethonium-induced complications during induction of general endotracheal anaesthesia. Afr J Med Med Sci. Mar. 2007;36(1):43-7. [pmid: 17876916].
Das UN. Folic acid says NO 1f40 to vascular diseases. [Review] [99 refs]. Nutrition. Jul. 2003;19(7–8):686-92. [pmid: 12831960].
Davey MJ, Teubner D. A randomized controlled trial of magnesium sulfate, in addition to usual care, for rate control in atrial fibrillation. Ann Emerg Med. Apr. 2005;45(4):347-53. [pmid: 15795711].
Davidson C. Potassium supplements and diuretics. La 1f40 ncet. Oct. 21. 1972;2(7782):882. [pmid: 4116593].
Davidson MH. Introduction. Am J Cardiol. 2006;98(4 SUPPL 1):1-2. [pmid: 16784909].
de Bree A, van Mierlo LA, Draijer R. Folic acid improves vascular reactivity in humans: a meta-analysis of randomized controlled trials. Am J Clin Nutr. Sep. 2007;86(3):610-7. [pmid: 17823424].
de Maat MP. Effects of diet, drugs, and genes on plasma fibrinogen levels. [Review] [113 refs]. Ann New York Acad Sci. 2001;936:509-21. [pmid: 11460508].
De LF, Panarese S, Gallerani R, et al. Angiotensin converting enzyme (ACE) inhibitory peptides: production and implementation of functional food. [Review] [231 refs]. Curr Pharm Des. 2009;15(31):3622-43. [pmid: 19925416].
de LM, Salen P. Mediterranean type of diet for the prevention of coronary heart disease. A global perspective from the seven countries study to the most recent dietary trials. [Review] [39 refs]. Int J Vitam Nutr Res. May. 2001;71(3):166-72. [pmid: 11582838].
Denas G, Marzot F, Offelli P, et al. Effectiveness and safety of a management protocol to correct over-anticoagulation with oral vitamin K: a retrospective study of 1,043 cases. J Thromb Thrombolysis. Apr. 2009;27(3):340-7. [pmid: 18338109].
Dequeker J. NSAIDs/corticosteroids--primum non nocere. [Review] [36 refs]. Adv Exp Med Biol. 1999;455:319-25. [pmid: 10599363].
Dergal JM, Gold JL, Laxer DA, et al. Potential interactions between herbal medicines and conventional drug therapies used by older adults attending a memory clinic. Drugs & Aging. 2002;19(11):879-86. [pmid: 12428996].
Deshaies EM, Boulos AS, Popp AJ. Peri-operative medical management of cerebral vasospasm. [Review] [65 refs]. Neurol Res. Jul. 2009;31(6):644-50. [pmid: 19133165].
Diaz R. Metabolic modulation of acute myocardial infarction. [Review] [9 refs]. Crit Care Clin. Apr. 2001;17(2):469-76. [pmid: 11450327].
Dib JG, Dedeyan S. Purported benefits of inositol niacinate. Am J Health-Syst Pharm. Feb. 1. 2004;61(3):307-8. [pmid: 14986567].
Dickerson RN. Warfarin resistance and enteral tube feeding: a vitamin K-independent interaction. [Review] [19 refs]. Nutrition. Oct. 2008;24(10):1048-52. [pmid: 18602249].
Diener HC, Weimar C. Update of secondary stroke prevention. [Review] [81 refs]. Nephrol Dial Transplant. Jun. 2009;24(6):1718-24. [pmid: 19244225].
DiPalma JR, McMichael R. Assessing the value of meganutrients in disease. Bull N Y Acad Med. Apr. 1982;58(3):254-62. [pmid: 6956410].
Dobiasova M, Frohlich J, Sedova M, et al. Cholesterol esterification and atherogenic index of plasma correlate with lipoprotein size and findings on coronary angiography. J Lipid Res. Mar. 2011;52(3):566-71. [pmid: 21224290].
Doddamani D, Kayastha A. Prostate cancer - What's new?. Medical Journal Armed Forces India. 2008;64(1):51-6.
Doherty JE. Digitalis glycosides. Pharmacokinetics and their clinical implications. [Review] [46 refs]. Ann Intern Med. Aug. 1973;79(2):229-38. [pmid: 4580113].
Doherty M, Smith PM. Effects of caffeine ingestion on exercise testing: a meta-analysis. Int J Sport Nutr Exerc Metab. Dec. 2004;14(6):626-46. [pmid: 15657469].
Dorhout Mees SM, van den Bergh WM, Algra A, et al. Achieved serum magnesium concentrations and occurrence of delayed cerebral ischaemia and poor outcome in aneurysmal subarachnoid haemorrhage. J Neurol Neurosurg Psychiatry. Jul. 2007;78(7):729-31. [pmid: 17135457].
Dorup I, Skajaa K, Thybo NK. Oral magnesium supplementation restores the concentrations of magnesium, potassium and sodium-potassium pumps in skeletal muscle of patients receiving diuretic treatment. Journal of Internal M 1f40 edicine. Feb. 1993;233(2):117-23. [pmid: 8381850].
Douglas JG. Clinical guidelines for the treatment of hypertension in African Americans. [Review] [42 refs]. Am J Cardiovasc Drugs. 2005;5(1):1-6. [pmid: 15631532].
Drinka PJ, Nolten WE. Hazards of treating osteoporosis and hypertension concurrently with calcium, vitamin D, and distal diuretics. J Am Geriatr Soc. May. 1984;32(5):405-7. [pmid: 6715769].
Du JR, Bai B, Yu Y, et al. The new progress of the study about volatile oil of the angelica. [Review] [47 refs] [Chinese]. Zhongguo Zhong Yao Za Zhi. Sep. 2005;30(18):1400-6. [pmid: 16381456].
Dumont L, Lysakowski C, Tram&#x00E8, et al. Magnesium for the prevention and treatment of acute mountain sickness. Clin Sci (Colch). Mar. 2004;106(3):269-77. [pmid: 14572305].
Dyckner T, Wester PO. Magnesium in cardiology. Acta Med Scand Suppl. 1982;661:27-31. [pmid: 6959475].
Eisenberg MJ. Magnesium deficiency and cardiac arrhythmias. [Review] [38 refs]. N Y State J Med. Mar. 1986;86(3):133-6. [pmid: 2422613].
Eisenstein M. A modern examination of an ancient cure. Lab anim. Feb. 2004;33(2):8-9. [pmid: 15235632].
el-Sherif N. Supraventricular tachycardia with AV block. Br Heart J. Jan. 1970;32(1):46-56. [pmid: 5417846].
Elkhouli AM. The efficacy of host response modulation therapy (omega-3 plus low-dose aspirin) as an adjunctive treatment of chronic periodontitis (clinical and biochemical study). J Periodontal Res. Apr. 2011;46(2):261-8. [pmid: 21261621].
Elliott J, Smith M. The acute management of intracerebral hemorrhage: a clinical review. [Review] [94 refs]. Anesth Analg. May. 2010;110(5):1419-27. [pmid: 20332192].
Ellis CJ, Scott R. Statins and coenzyme Q10. La 1f40 ncet. Mar. 29. 2003;361(9363):1134-5. [pmid: 12672343].
Elsayed RK, Evans JD. Emerging lipid-lowering drugs: squalene synthase inhibitors. [Review] [70 refs]. Expert Opin Emerg Drugs. Jun. 2008;13(2):309-22. [pmid: 18537523].
Emel'ianov AV, Goncharova VA, Sinitsina TM. The efficacy of the magnesium sulfate aerosol treatment of bronchial asthma patients. [Russian]. Ter Arkh. 1997;69(3):35-9. [pmid: 9229826].
Enas EA, Singh V, Munjal YP, et al. Recommendations of the Second Indo-US Health Summit on Prevention and Control of Cardiovascular Disease among Asian Indians. Indian Heart Journal. 2009;61(3):265-274. Date of Publication: May–June 2009 2009;(3):265–74. [pmid: 20503833].
Enstrom JE, Kanim LE, Klein MA. Vitamin C intake and mortality among a sample of the United States population. Epidemiology. May. 1992;3(3):194-202. [pmid: 1591317].
Ernst E. Cardiovascular effects of garlic (Allium sativum): a review. [Review] [80 refs]. Pharmatherapeutica. 1987;5(2):83-9. [pmid: 3310019].
Ernst E. The risk-benefit profile of commonly used herbal therapies: Ginkgo, St. John's wort, ginseng, echinacea, saw palmetto, and kava. Ann Intern Med. 2002;136(1):42-53. [pmid: 11777363].
Ernst E, Schmidt K. Ukrain: a new cancer cure? A systematic review of randomised clinical trials (Provisional abstract). BMC Cancer. 2005;5:69. [pmid: 15992405].
Ewy GA. Antioxidant therapy for coronary artery disease: don't paint the walls without treating the termites!. Arch Intern Med. Jun. 28. 1999;159(12):1279-80. [pmid: 10386503].
Fan J, Armitstead JA, Adams AG, et al. A retrospective evaluation of vitamin K1 therapy to reverse the anticoagulant effect of warfarin. Pharmacotherapy. Oct. 2003;23(10):1245-50. [pmid: 14594342].
Fang JC, Kinlay S, Beltrame J, et al. Effect of vitamins C and E on progression of transplant-associated arteriosclerosis: a randomised trial. La 1f40 ncet. Mar. 30. 2002;359(9312):1108-13. [pmid: 11943259].
Fang WS, Zhang J. Natural products. Curr Top Med Chem. 2009;9(16):1493. [pmid: 19929849].
Farber HI. Fever, vomiting, and liver dysfunction with procainamide therapy. Postgrad Med. Jul. 1974;56(1):155-6. [pmid: 4835003].
Farmer JA, Gotto AM Jr. Antihyperlipidaemic agents. Drug interactions of clinical significance. [Review] [36 refs]. Drug Saf. Nov. 1994;11(5):301-9. [pmid: 7873090].
Fatovich DM, Prentice DA, Dobb GJ. Magnesium in cardiac arrest (the magic trial). Resuscitation. Nov. 1997;35(3):237-41. [pmid: 10203402].
Faubert G, Lebel D, Bussieres JF. A pilot study to compare natural health product-drug interactions in two databases in Canada. Pharmacy World and Science. 2010;32(2):179-186. Date of Publication: April 2010 2010;(2):179–86. [pmid: 20077138].
Feng L, Sun Y. Treatment of ischemic apoplexy based on the theory of "lingering illness affecting collaterals". J Tradit Chin Med. Mar. 2007;27(1):55-8. [pmid: 17393629].
Fiore LD, Scola MA, Cantillon CE, et al. Anaphylactoid reactions to vitamin K. [Review] [29 refs]. J Thromb Thrombolysis. Apr. 2001;11(2):175-83. [pmid: 11406734].
Fisher M. Atherosclerosis: cellular aspects and potential interventions. [Review] [87 refs]. Cerebrovasc Brain Metab Rev. 1991;3(2):114-33. [pmid: 1854595].
Flamenbaum W. Metabolic consequences of antihypertensive therapy. Ann Intern Med. May. 1983;98(5 Pt 2):875-80. [pmid: 6847029].
Fletcher JE, Rosenberg H, Beech J. Interactions of fatty acids with the calcium release channel in malignant hyperthermia. Adv Exp Med Biol. 1991;301:57-69. [pmid: 1662466].
Fodor JG. Lifestyle modifications to prevent and control hypertension. 5. Recommendations on dietary salt. Canadian Hypertension Society, Canadian Coalition for High Blood Pressure Prevention and Control, Laboratory Centre for Disease Control at Health Canada, Heart and Stroke Foundation of Canada. CMAJ. 1999;160(9 Suppl):S29-S34. [pmid: 10333851].
Folkers K, Wolaniuk A. Research on coenzyme Q10 in clinical medicine and in immunomodulation. Drugs Exp Clin Res. 1985;11(8):539-45. [pmid: 3836873].
Fondevila CG, Grosso SH, Santarelli MT, et al. Reversal of excessive oral anticoagulation with a low oral dose of vitamin K1 compared with acenocoumarine discontinuation. A prospective, randomized, open study. Blood Coagul Fibrinolysis. Jan. 2001;12(1):9-16. [pmid: 11229833].
Forman DE, Rich MW. Management of acute myocardial infarction in the elderly. [Review] [149 refs]. Drugs & Aging. May. 1996;8(5):358-77. [pmid: 8935398].
Fraser GE. Diet and coronary heart disease: beyond dietary fats and low-density-lipoprotein cholesterol. [Review] [88 refs]. Am J Clin Nutr. May. 1994;59(5 Suppl):1117S-23S. [pmid: 8172111].
Freis ED. The chemotherapy of hypertension. [Review] [54 refs]. J Am Med Assoc. Nov. 15. 1971;218(7):1009-15. [pmid: 4398938].
Friday BA, Reinhart RA. Magnesium metabolism: a case report and literature review. [Review] [55 refs]. Crit Care Nurse. 1991;11(5):62-7. [pmid: 2026045].
Frishman WH, Beravol P, Carosella C. Alternative and Complementary Medicine for Preventing and Treating Cardiovascular Disease. Disease-a-Month. 2009;55(3):121-192. Date of Publication: March 2009 2009;(3):121–92. [pmid: 19215737].
Fumagalli S, Fattirolli F, Guarducci L, et al. Coenzyme Q10 terclatrate and creatine in chronic heart failure: a randomized, placebo-controlled, double-blind study. Clin Cardiol. Apr. 2011;34(4):211-7. [pmid: 21462215].
Gage BF, Milligan PE. Pharmacology and pharmacogenetics of warfarin and other coumarins when used with supplements. [Review] [22 refs]. Thromb Res. 2005;117(1–2):55-9. [pmid: 16043212].
Gagne L. Should everyone take supplements?. Explore: The Journal of Science and Healing. 2006;2(2):162-165. Date of Publication: Mar 2006 2006;(2):162–5.
Gaibazzi N, Ziacchi V. Reversibility of stress-echo induced ST-segment depression by long-term oral n-3 PUFA supplementation in subjects with chest pain syndrome, normal wall motion at stress-echo and normal coronary angiogram. BMC Cardiovasc Disord. Mar. 23. 2004;4:1. [pmid: 15038833].
Galløe A, Graudal N. Magnesium and myocardial infarction. La 1f40 ncet. May. 21. 1994;343(8908):1286-7. [pmid: 7910288].
Galløe AM, Graudal NA. Magnesium treatment of patients with acute myocardial infarction. A meta-analysis. Ugeskr Laeger. 1995;157(4):437-40. [pmid: 7846788].
Garg R, Malinow M, Pettinger M, et al. Niacin treatment increases plasma homocyst(e)ine levels. Am Heart J. Dec. 1999;138(6 Pt 1):1082-7. [pmid: 10577438].
Garipidou V. Oral anticoagulation - Past, present and future. HAEMA. 2005;8(SUPPL 1):S62-67.
Gaziano JM. In one HealthNews article, you wrote that vitamin C can lower your blood pressure, and in another you said that it increases the intima-media thickness (IMT), thereby increasing the risk of heart disease. Should I or shouldn't I take extra vitamin C?. Health News. Mar. 2001;7(3):10. [pmid: 11263083].
Geleijnse JM, Kok FJ, Grobbee DE. Blood pressure response to changes in sodium and potassium intake: a metaregression analysis of randomised trials. J Hum Hypertens. Jul. 2003;17(7):471-80. [pmid: 12821954].
Gelfand JM, Crawford GH, Brod BA, et al. Adverse cutaneous reactions to guggulipid. J Am Acad Dermatol. Mar. 2005;52(3 Pt 1):533-4. [pmid: 15761442].
Gerber JG, Kitch DW, Fichtenbaum CJ, et al. Fish oil and fenofibrate for the treatment of hypertriglyceridemia in HIV-infected subjects on antiretroviral therapy: Results of ACTG A5186. Journal of Acquired Immune Deficiency Syndromes. 2008;47(4):459-466. Date of Publication: Apr 2008 2008;(4):459–66. [pmid: 17971707].
Ghabril M, Chalasani N, Bjornsson E. Drug-induced liver injury: A clinical update. Current Opinion in Gastroenterology. 2010;26(3):222-226. Date of Publication: May 2010 2010;(3):222–6. [pmid: 20186054].
Gharavi AG, Diamond JA, Smith DA, et al. Niacin-induced myopathy. [Review] [11 refs]. Am J Cardiol. Oct. 15. 1994;74(8):841-2. [pmid: 7942568].
Ghio S, Scelsi L, Latini R, et al. Effects of n-3 polyunsaturated fatty acids and of rosuvastatin on left ventricular function in chronic heart failure: a substudy of GISSI-HF trial. Eur J Heart Fail. Dec. 2010;12(12):1345-53. [pmid: 20952767].
Goodnough LT, Shander AS. Recombinant factor VIIa: safety and efficacy. [Review] [40 refs]. Curr Opin Hematol. Sep. 2007;14(5):504-9. [pmid: 17934358].
Gordon NP, Schaffer DM. Use of dietary supplements by female seniors in a large Northern California health plan. BMC Geriatrics. 2005;5. Article Number: 4 Date of Publication: 09 Feb 2005 2005.
Gray DR, Morgan T, Chretien SD, et al. Efficacy and safety of controlled-release niacin in dyslipoproteinemic veterans. Ann Intern Med. Aug. 15. 1994;121(4):252-8. [pmid: 7741833].
Green D, O’Driscoll G, Rankin JM, et al. Beneficial effect of vitamin E administration on nitric oxide function in subjects with hypercholesterolaemia. Clin Sci (Colch). Sep. 1998;95(3):361-7. [pmid: 9730857].
Green PS, Vaisar T, Pennathur S, et al. Combined statin and niacin therapy remodels the high-density lipoprotein proteome. Circ Cardiovasc Qual Outcomes. Sep. 16. 2008;118(12):1259-67. [pmid: 18765395].
Grobler C, Callum J, McCluskey SA. Reversal of vitamin K antagonists prior to urgent surgery. [Review] [57 refs]. Can J Anaesth. May. 2010;57(5):458-67. [pmid: 20077167].
Gu W, Yang YZ, He MX. A study on combination therapy of Western and traditional Chinese medicine of acute viral myocarditis. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Dec. 1996;16(12):713-6. [pmid: 9772585].
Guarnieri C, Giordano E, Muscari C, et al. Vitamin E can protect myocardium against oxidative damage. Cardiovasc Res. Jul. 1995;30(1):153-5. [pmid: 7553718].
Gudbjarnason S. Dynamics of n-3 and n-6 fatty acids in phospholipids of heart muscle. [Review] [24 refs]. J Intern Med. Supplement. 1989;731:117-28. [pmid: 2650689].
Gulbahar O, Adisen H, Koca C, et al. Changes in serum carbonyl and malondialdehyde levels following colchicine and vitamin E treatment in Behcet’s disease. Methods Find Exp Clin Pharmacol. Oct. 2007;29(8):521-4. [pmid: 18040527].
Gunther KE, Conway G, Leibach L, et al. Low-dose oral vitamin K is safe and effective for outpatient management of patients with an INR>10. Thromb Res. 2004;113(3–4):205-9. [pmid: 15140584].
Gupta R, Singhal S, Goyle A, et al. Antioxidant and hypocholesterolaemic effects of Terminalia arjuna tree-bark powder: a randomised placebo-controlled trial. J Assoc Physicians India. Feb. 2001;49:231-5. [pmid: 11225136].
Guyton JR, Goldberg AC, Kreisberg RA, et al. Effectiveness of once-nightly dosing of extended-release niacin alone and in combination for hypercholesterolemia. Am J Cardiol. Sep. 15. 1998;82(6):737-43. [pmid: 9761083].
Guyton JR, Capuzzi DM. Treatment of hyperlipidemia with combined niacin-statin regimens. [Review] [29 refs]. Am J Cardiol. Dec. 17. 1998;82(12A):82U-4U. [pmid: 9671014].
Guyton JR. Treatment of hyperlipidemia with combined niacin-statin regimens. Am J Cardiol. 1998;82(12A):82U-4U. [pmid: 9671014].
Guyton JR. Combination regimens with statin, niacin, and intestinally active LDL-lowering drugs: alternatives to high-dose statin therapy?. [Review]. Curr Opin Lipidol. Aug. 2010;21(4):372-7. [pmid: 20625257].
Hadjiev D. Effects of nicotinic acid on cerebral and peripheral blood supply in attacks (rheoencephalographic and oscillographic studies). [German]. Psychiatr Neurol Med Psychol (Leipz ). Aug. 1965;17(8):291-6. [pmid: 5847589].
Halat KM, Dennehy CE. Botanicals and dietary supplements in diabetic peripheral neuropathy. Journal of the American Board of Family Practice. 2003;16(1):47-57. Date of Publication: Jan 2003 2003;(1):47–57. [pmid: 12583650].
Hamblin L, Laird A, Parkes E, et al. Improved arthritic knee health in a pilot RCT of phytotherapy. Journal of The Royal Society for the Promotion of Health. 2008;128(5):255-262. Date of Publication: September 2008 2008;(5):255–62. [pmid: 18814408].
Hampton EM, Whang DD, Whang R. Intravenous magnesium therapy in acute myocardial infarction. [Review] [54 refs]. Ann Pharmacother. Feb. 1994;28(2):212-9. [pmid: 8173140].
Hannan F, Davoren P. Use of nicotinic acid in the management of recurrent hypoglycemic episodes in diabetes. Diabetes Care. Jul. 2001;24(7):1301. [pmid: 11423523].
Hansen SN, Harris WS. New evidence for the cardiovascular benefits of long chain omega-3 fatty acids. [Review] [24 refs]. Curr Atheroscler Rep. Dec. 2007;9(6):434-40. [pmid: 18377782].
Hanslik T, Viboud C, Chadenat ML, et al. Vitamin K in anticoagulation therapy. La 1f40 ncet. Feb. 24. 2001;357(9256):637. [pmid: 11558516].
Hao Y, Kong X-Y, Wu T-X. Assessment of the safety of Qin Kai Ling injection: A systematic review. Chin J Evid -Based Med. 2010;10(2):162-75.
Hartshorn EA. Food and drug interactions. J Am Diet Assoc. Jan. 1977;70(1):15-9. [pmid: 830703].
Hasler CM, Kundrat S, Wool D. Functional foods and cardiovascular disease. [Review] [75 refs]. Curr Atheroscler Rep. Nov. 2000;2(6):467-75. [pmid: 11122780].
Hayashi Y, Ohtani M, Hiraishi T, et al. “Initial, continuous and intermittent bolus” administration of minimally-diluted blood cardioplegia supplemented with 1f40 potassium and magnesium for hypertrophied hearts. Heart Lung Circ. Oct. 2006;15(5):325-31. [pmid: 16926119].
HAYES, Inc. Horse chestnut (aesculus Hippocastanum L.) for chronic venous insufficiency (Structured abstract). Lansdale, Pa. Hayes, Inc. 2008.
Hazelrigg SR, Boley TM, Cetindag IB, et al. The efficacy of supplemental magnesium in reducing atrial fibrillation after coronary artery bypass grafting. Ann Thorac Surg. Mar. 2004;77(3):824-30. [pmid: 14992881].
Heinonen L, Kohvakka A, Pietinen P, et al. Role of dietary potassium and magnesium in diuretic-treated patients with cardiac insufficiency. Magnesium. 1984;3(1):38-45. [pmid: 6482509].
Heng MK, Norris RM, Singh BN, et al. Effects of glucose and glucose-insulin-potassium on haemodynamics and enzyme release after acute myocardial infarction. Br Heart J. Jul. 1977;39(7):748-57. [pmid: 328028].
Henry DA, Lowe JM, Lawson DA, et al. The changing pattern of toxicity of digoxin. Postgrad Med J. Jun. 1981;57(668):358-62. [pmid: 7301680].
Herrera-Arellano A, Flores-Romero S, vez-Soto MA, et al. Effectiveness and tolerability of a standardized extract from Hibiscus sabdariffa in patients with mild to moderate hypertension: a controlled and randomized clinical trial. Phytomedicine. Jul. 2004;11(5):375-82. [pmid: 15330492].
Herzog WR, Serebruany VL. How magnesium therapy may influence clinical outcome in acute myocardial infarction: review of potential mechanisms. [Review] [50 refs]. Coron Artery Dis. May. 1996;7(5):364-70. [pmid: 8866202].
Hicks JJ, Montes-Cortes DH, Cruz-Dominguez MP, et al. Antioxidants decrease reperfusion induced arrhythmias in myocardial infarction with ST-elevation. Front Biosci. 2007;12:2029-37. [pmid: 17127441].
Hirnerova E, Krahulec B, Strbova L, et al. Effect of vitamin E supplementation on microalbuminuria, lipid peroxidation and blood prostaglandins in diabetic patients. Bratisl Lek Listy. 2004;105(12):408-13. [pmid: 15777070].
Hirsh J, Cade JF, Gallus AS. Anticoagulants in pregnancy: a review of indications and complications. [Review] [39 refs]. Am Heart J. Mar. 1972;83(3):301-5. [pmid: 4551025].
Hirsh J, Gallus AS. Anticoagulants in venous thromboembolism. Prophylactic and therapeutic use. [Review] [44 refs]. Postgrad Med. Jan. 1974;55(1):211-7. [pmid: 4588719].
Hitzenberger G, Rehak PH. The effect of a homeopathic drug on the blood pressure of hypertensive patients--a randomised double-blind controlled parallel group comparative trial. [German]. Wien Med Wochenschr. Sep. 2005;155(17–18):392-6. [pmid: 16392436].
Hoffer A. Niacin reaction. J Fam Pract. Jun. 1992;34(6):677-1. [pmid: 1593238].
Hofmeyr GJ, Duley L, Atallah A. Dietary calcium supplementation for prevention of pre-eclampsia and related problems: a systematic review and commentary. BJOG. Aug. 2007;114(8):933-43. [pmid: 17565614].
Hogg RJ, Fitzgibbons L, Atkins C, et al. Efficacy of omega-3 fatty acids in children and adults with IgA nephropathy is dosage- and size-dependent. Clin J Am Soc Nephrol. Nov. 2006;1(6):1167-72. [pmid: 17699343].
Holdcraft LC, Assefi N, Buchwald D. Complementary and alternative medicine in fibromyalgia and related syndromes. Best Practice and Research in Clinical Rheumatology. 2003;17(4):667-683. Date of Publication: Aug 2003 2003;(4):667–83.
Holzgreve H. Therapy of cardiac insufficiency with diuretics. [German]. Fortschr Med Orig. Aug. 26. 1982;100(31–32):1449-56. [pmid: 7129304].
Hong MY, Seeram NP, Zhang Y, et al. Chinese red yeast rice versus lovastatin effects on prostate cancer cells with and without androgen receptor overexpression. J med food. Dec. 2008;11(4):657-66. [pmid: 19053857].
Horrobin DF. Essential fatty acids, prostaglandins, and alcoholism: an overview. [Review] [103 refs]. Alcohol Clin Exp Res. Feb. 1987;11(1):2-9. [pmid: 3032012].
Houweling AH, Vanstone CA, Trautwein EA, et al. Baseline plasma plant sterol concentrations do not predict changes in serum lipids, C-reactive protein (CRP) and plasma plant sterols following intake of a plant sterol-enriched food. European Journal of Clinical Nutrition. 2009;63(4):543-551. Date of Publication: 2009 2009;(4):543–51. [pmid: 18073779].
Huraib S, Tanimu D, Shaheen F, et al. Effect of vitamin-E-modified dialysers on dialyser clotting, erythropoietin and heparin dosage: a comparative crossover study. Am J Nephrol. Sep. 2000;20(5):364-8. [pmid: 11092992].
Iacoviello L, Amore C, De CA, et al. Modulation of fibrinolytic response to venous occlusion in humans by a combination of low-dose aspirin and n-3 polyunsaturated fatty acids. Arterioscler Thromb. Oct. 1992;12(10):1191-7. [pmid: 1390591].
Illingworth DR, Bacon S. Hypolipidemic effects of HMG-CoA reductase inhibitors in patients with hypercholesterolemia. [Review] [50 refs]. Am J Cardiol. Oct. 30. 1987;60(12):33G-42G. [pmid: 3604942].
Inciardi JA. Over-the-counter-drugs: epidemiology, adverse reactions, overdose deaths, and mass media promotion. Addict Dis. 1977;3(2):253-72. [pmid: 28642].
Isbister GK, Dawson A, Isbister JP. Recommendations for the management of over-anticoagulation with warfarin. [Review] [15 refs]. Emerg Med (Fremantle). Dec. A. 2001;13(4):469-71. [pmid: 11903434].
Ishikawa S, Kario K. Does eicosapentaenoic acid truly reduce atherosclerosis?. Hypertension Research. 2009;32(11):934-935. Date of Publication: 2009 2009;(11):934–5. [pmid: 19763136].
Ishiyama T, Morita Y, Toyama S, et al. A clinical study of the effect of coenzyme Q on congestive heart failure. Jpn 1f40. Jan. 1976;17(1):32-42. [pmid: 778433].
Itagaki S, Ochiai A, Kobayashi M, et al. Interaction of coenzyme Q10 with the intestinal drug transporter P-glycoprotein. J Agric Food Chem. Aug. 27. 2008;56(16):6923-7. [pmid: 18656939].
Ix JH, Ganjoo P, Tipping D, et al. Sustained hypophosphatemic effect of once-daily niacin/laropiprant in dyslipidemic CKD stage 3 patients. Am J Kidney Dis. Jun. 2011;57(6):963-5. [pmid: 21496982].
Izzo AA, Di Carlo G, Borrelli F, et al. Cardiovascular pharmacotherapy and herbal medicines: the risk of drug interaction. [Review] [81 refs]. Int J Cardiol. Jan. 2005;98(1):1-14. [pmid: 15676159].
Jacobson TA. A “hot” topic in dyslipidemia management--“how to beat a flush”: optimizing niacin tolerability to promote long-term treatment adherence and coronary disease prevention. [Review] [150 refs]. Mayo Clin Proc. Apr. 2010;85(4):365-79. [pmid: 20360295].
Jaffer FA. Assessing niacin as an atherosclerosis therapeutic agent valuable insights provided by high-resolution vascular magnetic resonance imaging. J Am Coll Cardiol. Nov. 3. 2009;54(19):1795-6. [pmid: 19874993].
James JE, Gregg ME, Kane M, et al. Dietary caffeine, performance and mood: enhancing and restorative effects after controlling for withdrawal reversal. Neuropsychobiology. 2005;52(1):1-10. [pmid: 15942257].
Janiger JL, Cheng JW. Glucose-insulin-potassium solution for acute myocardial infarction. [Review] [14 refs]. Ann Pharmacother. Jun. 2002;36(6):1080-4. [pmid: 12022912].
Janssens D, Michiels C, Guillaume G, et al. Increase in circulating endothelial cells in patients with primary chronic venous insufficiency: protective effect of Ginkor Fort in a randomized double-blind, placebo-controlled clinical trial. J Cardiovasc Pharmacol. Jan. 1999;33(1):7-11. [pmid: 9890390].
Jelliffe RW. Factors to consider in planning digoxin therapy. J Chronic Dis. Sep. 1971;24(7):407-16. [pmid: 5136237].
Jenkins DJA, Sievenpiper JL, Pauly D, et al. Are dietary recommendations for the use of fish oils sustainable?. CMAJ Canadian Medical Association Journal. 2009;180(6):633-637. Date of Publication: 17 Mar 2009 2009;(6):633–7.
Jeschke E, Ostermann T, Lu KC, et al. Remedies containing asteraceae extracts: A prospective observational study of prescribing patterns and adverse drug reactions in german primary care. Drug Saf. 2009;32(8):691-706. [pmid: 19591533].
Jeya M, Moon H-J, Lee J-L, et al. Current state of coenzyme Q10 production and its applications. Applied Microbiology and Biotechnology. 2010;85(6):1653-1663. Date of Publication: February 2010 2010;(6)1653–63. [pmid: 20012276].
Jialal I, Amess W, Kaur M. Management of hypertriglyceridemia in the diabetic patient. [Review] [24 refs]. Curr Diabetes Rep. Aug. 2010;10(4):316-20. [pmid: 20532703].
Jiang Q, Cao W, Tang X, et al. Tripterygium wilfordii extract for treating rheumatoid arthritis: systematic review (Provisional abstract). China Journal of Chinese Materia Medica. 2009;34:2637-43. [pmid: 20069910].
Jin M, Qin J, Wu W. Clinical study on “sini” decoction in treating stenocardia for coronary heart disease. [Chinese]. Zhong Yao Cai. Jan. 2003;26(1):71-3. [pmid: 12858776].
Johansson JO, Egberg N, Asplund-Carlson A, et al. Nicotinic acid treatment shifts the fibrinolytic balance favourably and decreases plasma fibrinogen in hypertriglyceridaemic men. J Cardiovasc Risk. Jun. 1997;4(3):165-71. [pmid: 9475670].
Jones PH. Expert perspective: reducing cardiovascular risk in metabolic syndrome and type 2 diabetes mellitus beyond low-density lipoprotein cholesterol lowering. [Review] [69 refs]. Am J Cardiol. Dec. 22. 2008;102(12A):41L-7L. [pmid: 19084089].
Jungnickel PW, Maloley PA, Vander Tuin EL, et al. Effect of two aspirin pretreatment regimens on niacin-induced cutaneous reactions. J Gen Intern Med. Oct. 1997;12(10):591-6. [pmid: 9346454].
Kamanna VS, Vo A, Kashyap ML. Nicotinic acid: recent developments. [Review] [39 refs]. Curr Opin Cardiol. Jul. 2008;23(4):393-8. [pmid: 18520725].
Kamanna VS, Ganji SH, Kashyap ML. The mechanism and mitigation of niacin-induced flushing. [Review]. Int J Clin Pract. Sep. 2009;63(9):1369-77. [pmid: 19691622].
Kamerling R. Potassium supplementation with diuretics. [Dutch]. Ned Tijdschr Geneeskd. Oct. 8. 1988;132(41). 1899. [pmid: 3185785].
Kandziora J. Crataegutt effect in coronary blood circulation disorders. EEG findings in exercise test. [German]. Munch Med Wochenschr. Feb. 7. 1969;111(6):295-8. [pmid: 5819090].
Kane JP, Havel RJ. Treatment of hypercholesterolemia. [Review] [29 refs]. Annu Rev Med. 1986;37:427-35. [pmid: 3518611].
Kaplan NM. Long-term effectiveness of nonpharmacological treatment of hypertension. [Review] [58 refs]. Hypertension. Sep. 1991;18(3 Suppl):I153-160. [pmid: 1889854].
Kaplon RJ, Gillinov AM, Smedira NG, et al. Vitamin K reduces bleeding in left ventricular assist device recipients. J Heart Lung Transplant. Apr. 1999;18(4):346-50. [pmid: 10226899].
Karas RH, Kashyap ML, Knopp RH, et al. Long-term safety and efficacy of a combination of niacin extended release and simvastatin in patients with dyslipidemia: the OCEANS study. Am J Cardiovasc Drugs. 2008;8(2):69-81. [pmid: 18422390].
Kaverina NV, Chumburidze VB. Antianginal drugs. [Review] [330 refs]. Pharmacol Ther. 1979;4(1):109-53. [pmid: 88742].
Kazmier FJ. Current practice with vitamin K antagonist therapy. [Review] [49 refs]. Mayo Clin Proc. Dec. 1974;49(12):918-22. [pmid: 4216730].
Keith M, Mazer CD, Mikhail P, et al. Coenzyme Q10 in patients undergoing CABG: Effect of statins and nutritional supplementation. Nutr Metab Cardiovasc Dis. Feb. 2008;18(2):105-11. [pmid: 17368873].
Kemp G, Kemp D. Diuretics. Am. Jun. 1978;78(6):1006-10. [pmid: 248257].
Kendall MJ, Nuttall SL, Martin U. Antioxidant therapy--a new therapeutic option for reducing mortality from coronary artery disease. J Clin Pharm Ther. Oct. 1998;23(5):323-5. [pmid: 9875678].
Key N. Comparison of oral versus intravenous phytonadione in patients with excessive anticoagulation. Curr Hematol Rep. Sep. 2004;3(5):315-6. [pmid: 15341696].
Khandelwal P, Mathur A. Potassium supplement in controlling mild hypertension. In Fourth International Symposium on Cardiovascular Pharmacotherapy. 1991 Apr 21. 1991.
Khatchadourian J, Pak CY. Nephrolithiasis Curr Ther Endocrinol Metab. 1994;5:528-32. [pmid: 7704788].
Khedun SM, Naicker T, Maharaj B. Zinc, hydrochlorothiazide and sexual dysfunction. Cent Afr J Med. Oct. 1995;41(10):312-5. [pmid: 8556776].
Killewich LA. Improving functional status and quality of life in elderly patients with peripheral arterial disease. J Am Coll Surg. 2006;202(2):345-55. [pmid: 16427563].
Kim KH, Choi WS, Lee JH, et al. Relationship between dietary vitamin K intake and the stability of anticoagulation effect in patients taking long-term warfarin. Thromb Haemost. Oct. 2010;104(4):755-9. [pmid: 20664899].
Kim TE, Kim BH, Kim J, et al. Comparison of the pharmacokinetics of ticlopidine between administration of a combined fixed-dose tablet formulation of ticlopidine 250 mg/ginkgo extract 80 mg, and concomitant administration of ticlopidine 250-mg and ginkgo extract 80-mg tablets: an open-label, two-treatment, single-dose, randomized-sequence crossover study in healthy Korean male volunteers. Clin Ther. Oct. 2009;31(10):2249-57. [pmid: 19922896].
Klevay LM, Milne DB. Low dietary magnesium increases supraventricular ectopy. Am J Clin Nutr. Mar. 2002;75(3):550-4. [pmid: 11864862].
Kligler B, Lynch D. An integrative approach to the management of type 2 diabetes mellitus. Alternative Therapies in Health and Medicine. 9(6):24-33+106. 2003 Date of Publication: Nov 2003 2003;(6):24–33+106. [pmid: 14618854].
Klosterman HJ. Vitamin B6 antagonists of natural origin. [Review] [51 refs]. J Agric Food Chem. Jan. 1974;22(1):13-6. [pmid: 4590576].
Knodel LC, Talbert RL. Adverse effects of hypolipidaemic drugs. [Review] [186 refs]. Med Toxicol. Jan. 1987;2(1):10-32. [pmid: 3547004].
Knopp RH. New approaches to cholesterol lowering: efficacy and safety. [Review] [37 refs]. Hosp Pract (Off Ed). Jun. Suppl 1. 1988;23:22-30. [pmid: 3134382].
Knox DL, Chen MF, Guilarte TR, et al. Nutritional amblyopia. Folic acid, vitamin B-12, and other vitamins. [Review] [12 refs]. Retina. 1982;2(4):288-93. [pmid: 6101136].
Kobayashi N, Nakamura M, Hiramori K. Effects of infusion of L-arginine on exercise-induced myocardial ischemic ST-segment changes and capacity to exercise of patients with stable angina pectoris. Coron Artery Dis. Jul. 1999;10(5):321-6. [pmid: 10421972].
Koch E. Inhibition of platelet activating factor (PAF)-induced aggregation of human thrombocytes by ginkgolides: considerations on possible bleeding complications after oral intake of Ginkgo biloba extracts. Phytomedicine. Jan. 2005;12(1–2):10-6. [pmid: 15693702].
Koh KK, Blum A, Hathaway L, et al. Vascular effects of estrogen and vitamin E therapies in postmenopausal women. Circ Cardiovasc Qual Outcomes. Nov. 2. 1999;100(18):1851-7. [pmid: 10545428].
Kohno H, Koyanagi T, Kasegawa H, et al. Three-day magnesium administration prevents atrial fibrillation after coronary artery bypass grafting. [Review] [29 refs]. Ann Thorac Surg. Jan. 2005;79(1):117-26. [pmid: 15620927].
Kohvakka A, Heinonen L, Pietinen P, et al. Potassium and magnesium balance in thiazide-treated cardiac patients with special reference to diet. Acta Med Scand Suppl. 1982;668:102-9. [pmid: 6963086].
Kolpakchi AL, Chukwu II, Vlachaki MT. Red yeast rice for dyslipidemia in statin-intolerant patients. Annals of Internal Medicine. 2010;152(2):133-134. Date of Publication: 19 Jan 2010 2010;(2):133–4. [pmid: 20083838].
Koniari I, Apostolakis E, Rogkakou C, et al. Pharmacologic prophylaxis for atrial fibrillation following cardiac surgery: a systematic review. [Review]. J Cardiothorac Surg. 2010;5:121. [pmid: 21118555].
Költringer P, Langsteger W, Klima G, et al. Hemorheologic effects of ginkgo biloba extract EGb 761. Dose-dependent effect of EGb 761 on microcirculation and viscoelasticity of blood. Fortschr Med Orig. 1993;111(10):170-2.
Krämer KD, Ghabussi P, Hochrein H. Antihypertensive combination-therapy with inositol nicotinate in essential hypertension. Die Medizinische Welt. 1977;28(27):1198-201. [pmid: 329049].
Krikler D. Verapamil in cardiology. Eur J Cardiol. Aug. 1974;2(1):3-10. [pmid: 4153535].
Kris-Etherton PM. Antioxidants blunt high-density lipoprotein response to statin plus niacin therapy. Curr Atheroscler Rep. Nov. 2001;3(6):435-6. [pmid: 11602062].
Kruger WD, Evans AA, Wang L, et al. Polymorphisms in the CBS gene associated with decreased risk of coronary artery disease and increased responsiveness to total homocysteine lowering by folic acid. Mol Genet Metab. May. 2000;70(1):53-60. [pmid: 10833331].
Kuncl RW. Agents and mechanisms of toxic myopathy. [Review] [64 refs]. Curr Opin Neurol. Oct. 2009;22(5):506-15. [pmid: 19680127].
Kunisaki M, Umeda F, Inoguchi T, et al. Effects of vitamin E administration on platelet function in diabetes mellitus. DIABETES RES. May. 1990;14(1):37-42. [pmid: 2134664].
Kurian GA, Paddikkala J. N-acetylcysteine and magnesium improve biochemical abnormalities associated with myocardial ischaemic reperfusion in South Indian patients undergoing coronary artery bypass grafting: a comparative analysis. Singapore Med J. May. 2010;51(5):381-8. [pmid: 20593142].
Kwiterovich PO Jr. The antiatherogenic role of high-density lipoprotein cholesterol. [Review] [60 refs]. Am J Cardiol. Nov. 5. 1998;82(9A):13Q-21Q. [pmid: 9671001].
Lamarine RJ. Selected health and behavioral effects related to the use of caffeine. [Review] [105 refs]. J Community Health. Dec. 1994;19(6):449-66. [pmid: 7844249].
Lambert ML Jr. Drug and diet interactions. Am. Mar. 1975;75(3):402-6. [pmid: 234681].
Lamperti C, Naini AB, Lucchini V, et al. Muscle coenzyme Q10 level in statin-related myopathy. Arch Neurol. Nov. 2005;62(11):1709-12. [pmid: 16286544].
Landmark K, Reikvam A. Meta-analyses, magnesium and acute myocardial infarction. [Norwegian]. Tidsskr Nor Laegeforen. Jan. 10. 2001;121(1):97-8. [pmid: 12013626].
Langer G, Grossmann K, Saal S, et al. Nutritional interventions for liver-transplanted patients. Cochrane Database Syst Rev. 2009;(1).
Langsjoen PH, Langsjoen PH, Folkers K. Long-term efficacy and safety of coenzyme Q10 therapy for idiopathic dilated cardiomyopathy. Am J Cardiol. Feb. 15. 1990;65(7):521-3. [pmid: 2305693].
Lankin VZ, Tikhaze AK, Konovalova GG, et al. Intensification of free radical oxidation of low-density lipoproteins in the plasma of patients with ischemic heart disease receiving beta-hydroxy-beta-methylglutaryl-coenzyme A reductase inhibitor cerivastatin and inhibition of low-density lipoprotein peroxidation with antioxidant probucol. Bull Exp Biol Med. Jul. 2002;134(1):39-42. [pmid: 12459865].
Lapi F, Gallo E, Bernasconi S, et al. Myopathies associated with red yeast rice and liquorice: spontaneous reports from the Italian Surveillance System of Natural Health Products. Br J Clin Pharmacol. Oct. 2008;66(4):572-4. [pmid: 18637891].
Lee HS, Tardif JC, Harel F, et al. Effects of plaque composition on vascular remodelling after angioplasty in the MultiVitamins and Probucol (MVP) trial. Can J Cardiol. Mar. 2002;18(3):271-5. [pmid: 11907616].
Lee IM, Cook NR, Manson JE, et al. Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women’s Health Study. J Natl Cancer Inst. Dec. 15. 1999;91(24):2102-6. [pmid: 10601381].
Lee JM, Robson MD, Yu LM, et al. Effects of high-dose modified-release nicotinic acid on atherosclerosis and vascular function: a randomized, placebo-controlled, magnetic resonance imaging study. J Am Coll Cardiol. Nov. 3. 2009;54(19):1787-94. [pmid: 19874992].
Leemhuis MP, Struyvenberg A. Significance of hypokalaemia due to diuretics. [Review] [89 refs]. Neth J Med. 1973;16(1):18-28. [pmid: 4572424].
Leitha T. Effectiveness of coronary heart disease risk management in high-risk patients. Clin Cardiol. 1994;17(3):123-30. [pmid: 8168280].
Lemann J Jr, Gray RW, Maierhofer WJ, et al. Hydrochlorothiazide inhibits bone resorption in men despite experimentally elevated serum 1,25-dihydroxyvitamin D concentrations. Kidney Int. Dec. 1985;28(6):951-8. [pmid: 3003445].
Lewis WH. Iatrogenic psychotic depressive reaction in hypertensive patients. Am J Psychiatry. Apr. 1971;127(10):1416-7. [pmid: 5549939].
Li W, Tang L, Wu T, et al. Chinese herbal medicines for treating pre-eclampsia [Cochrane review]. Cochrane Database of Systematic Reviews. Chichester (UK). John Wiley & Sons, Ltd. 2006. 2006;(2):2.
Lichtenstein AH. Plant sterols and blood lipid levels. [Review] [37 refs]. Curr Opin Clin Nutr Metab Care. Mar. 2002;5(2):147-52. [pmid: 11844980].
Lin TH, Voon WC, Yen HW, et al. Randomized comparative study of the effects of treatment with once-daily, niacin extended-release/lovastatin and with simvastatin on lipid profile and fibrinolytic parameters in Taiwan. Kaohsiung J Med Sci. Jun. 2006;22(6):257-65. [pmid: 16793562].
Linke A, Sonnabend M, Fasshauer M, et al. Effects of extended-release niacin on lipid profile and adipocyte biology in patients with impaired glucose tolerance. Atherosclerosis. Jul. 2009;205(1):207-13. [pmid: 19131065].
Liu DL, Pan ZR, Huang ZL. Different doses and routes of magnesium sulfate administration in treating severe preeclamptic and eclamptic patients. Chin Med J. May. 1982;95(5):363-6. [pmid: 6814850].
Liu T, Wang CH, Yang J. Modified sanjiasan decoction in regulating intelligence state of patients with vascular dementia. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Jun. 2005;25(6):492-5. [pmid: 16025959].
Loots D, Oosthuizen W, Pieters M, et al. Foodstate vitamin C complex may beneficially affect haemostasis and fibrin network structure in hyperlipidaemic patients. Blood Coagul Fibrinolysis. Oct. 2004;15(8):677-85. [pmid: 15613923].
Lopes de Faria JB, Friedman R, de CS, et al. Renal functional response to protein loading in type 1 (insulin-dependent) diabetic patients on normal or high salt intake. Nephron. 1997;76(4):411-7. [pmid: 9274838].
Luria MH, Sapoznikov D. Raising HDL cholesterol with low-dose nicotinic acid and bezafibrate: preliminary experience. Postgrad Med J. Apr. 1993;69(810):296-9. [pmid: 8321794].
Ma L, Liu WG, Zhang JM, et al. Magnesium sulphate in the management of patients with aneurysmal subarachnoid haemorrhage: a meta-analysis of prospective controlled trials (Provisional abstract). Brain Injury. 2010;24:730-5. [pmid: 20334471].
Maas AI, Murray GD. Magnesium for neuroprotection after traumatic brain injury. Lancet neurol. Jan. 2007;6(1):20-1. [pmid: 17166797].
Maccubbin D, Bays HE, Olsson AG, et al. Lipid-modifying efficacy and tolerability of extended-release niacin/laropiprant in patients with primary hypercholesterolaemia or mixed dyslipidaemia. Int J Clin Pract. Dec. 2008;62(12):1959-70. [pmid: 19166443].
Maccubbin D, Tipping D, Kuznetsova O, et al. Hypophosphatemic effect of niacin in patients without renal failure: a randomized trial. Clin J Am Soc Nephrol. Apr. 2010;5(4):582-9. [pmid: 20299362].
MacDonald MB, Sawatzky JE, Wilson TW, et al. Predicting success in antihypertensive drug therapy: the importance of nondrug variables. Can J Cardiol. Jan. 1991;7(1):19-23. [pmid: 2025785].
Machlin LJ. Use and safety of elevated dosages of vitamin E in adults. [Review] [72 refs]. Int J Vitam Nutr Res Suppl. 1989;30:56-68. [pmid: 2507707].
Maffly RH. How to avoid complications of potent diuretics. J Am Med Assoc. Jun. 7. 1976;235(23k0):2526-8. [pmid: 946673].
Makris M, Watson HG. The management of coumarin-induced over-anticoagulation Annotation. [Review] [50 refs]. Br J Haematol. Aug. 2001;114(2):271-80. [pmid: 11529844].
Makris M, van Veen JJ, Maclean R. Warfarin anticoagulation reversal: management of the asymptomatic and bleeding patient. [Review] [67 refs]. J Thromb Thrombolysis. Feb. 2010;29(2):171-81. [pmid: 19882303].
Malinow MR. Homocyst(e)ine, vitamins and genetic interactions in vascular disease. Can J Cardiol. Suppl. 1999;15:B31B-34B. 34B.
Malve H, Kerkar P, Mishra N, et al. LDL-cholesterol lowering activity of a blend of rice bran oil and safflower oil (8:2) in patients with hyperlipidaemia: a proof of concept, double blind, controlled, randomised parallel group study. J Indian Med Assoc. Nov. 2010;108(11):785-8. [pmid: 21510583].
Manz M, Jung W, Lüderitz B. Effect of magnesium on sustained ventricular tachycardia. [Review] [11 refs] [German]. Herz. Jun. Suppl 1. 1997;22:51-5. [pmid: 9333592].
Marcoff L, Thompson PD. The role of coenzyme Q10 in statin-associated myopathy: a systematic review. [Review] [48 refs]. J Am Coll Cardiol. Jun. 12. 2007;49(23):2231-7. [pmid: 17560286].
Marder VJ, Ortel TL, Grollman A, et al. Thrombosis Research: Preface. Thrombosis Research. 2005;117(1–2):1-3. Date of Publication 2005 2005;(1–2):1–3.
Marder VJ. The interaction of dietary supplements with antithrombotic agents: Scope of the problem. Thrombosis Research. 2005;117(1–2):7-13. Date of Publication 2005 2005;(1–2):7–13. [pmid: 16076481].
Mariscalco G, Cederlund B, Engstr&#x00F6, et al. The clinical noncompliance of oral sotalol/magnesium for prophylactic treatment of atrial fibrillation after coronary artery bypass grafting. J Card Surg. Jul. 2007;22(4):281-6. [pmid: 17661767].
Marongiu F, Sorano GG, Conti M, et al. Known vitamin K intake and management of poorly controlled oral anticoagulant therapy. La 1f40 ncet. Aug. 29. 1992;340(8818):545-6. [pmid: 1354291].
Martin KJ, Gonzalez EA. Vitamin D supplementation in CKD. [Review]. Clin Nephrol. Apr. 2011;75(4):286-93. [pmid: 21426882].
Mason DT, Braunwald E. Digitalis: new facts about an old drug. [Review] [65 refs]. Am J Cardiol. Aug. 1968;22(2):151-61. [pmid: 4874956].
Mastropietro C. Digitalis: an overview. AANA J. Jun. 1983;51(3):261-6. [pmid: 6310923].
Matthan NR, Giovanni A, Schaefer EJ, et al. Impact of simvastatin, niacin, and/or antioxidants on cholesterol metabolism in CAD patients with low HDL. J Lipid Res. Apr. 2003;44(4):800-6. [pmid: 12562840].
McCall D, Walsh RA, Frohlich ED, et al. Calcium entry blocking drugs: mechanisms of action, experimental studies and clinical uses. [Review] [260 refs]. Curr Probl Cardiol. Aug. 1985;10(8):1-80. [pmid: 2414067].
McCormack PL, Keating GM. Prolonged-release nicotinic acid: a review of its use in the treatment of dyslipidaemia. [Review] [55 refs]. Drugs. 2005;65(18):2719-40. [pmid: 16392885].
McGlasson DL. Oral anticoagulants. [Review] [32 refs]. Clin Lab Sci. 2004;17(2):107-12. [pmid: 15168892].
McKenna DJ, Jones K, Hughes K. Efficacy, safety, and use of ginkgo biloba in clinical and preclinical applications. [Review] [127 refs]. Altern Ther Health Med. Sep. 1988;7(5):70-86. [pmid: 11565403].
McKenney JM. Lovastatin: a new cholesterol-lowering agent. [Review] [74 refs]. Clin Pharm. Jan. 1988;7(1):21-36. [pmid: 3278832].
McLean RM. Magnesium and its therapeutic uses: a review. [Review] [130 refs]. Am J Med. Jan. 1994;96(1):63-76. [pmid: 8304365].
Metelitsina TI, Grunwald JE, DuPont JC, et al. Effect of niacin on the choroidal circulation of patients with age related macular degeneration. Br J Ophthalmol. Dec. 2004;88(12):1568-72. [pmid: 15548814].
Meydani SN, Lichtenstein AH, White PJ, et al. Food use and health effects of soybean and sunflower oils. [Review] [222 refs]. J Am Coll Nutr. Oct. 1991;10(5):406-28. [pmid: 1955619].
Michael B, Coyne DW, Fishbane S, et al. Sodium ferric gluconate complex in hemodialysis patients: adverse reactions compared to placebo and iron dextran. Kidney Int. May. 2002;61(5):1830-9. [pmid: 11967034].
Michon P. Level of total and ionized magnesium fraction based on biochemical analysis of blood and hair and effect of supplemented magnesium (Slow Mag B6) on selected parameters in hypertension of patients treated with various groups of drugs. [Polish]. Ann Acad Med Stetin. 2002;48:85-97. [pmid: 14601471].
Mickle DA, Weisel RD. Future directions of vitamin E and its analogues in minimizing myocardial ischemia-reperfusion injury. [Review] [19 refs]. Can J Cardiol. Jan. 1993;9(1):89-93. [pmid: 8439833].
Mimran A, Ribstein J, duCailar G. Contrasting effect of antihypertensive treatment on the renal response to L-arginine. Hypertension. Dec. 1995;26(6 Pt 1):937-41. [pmid: 7490152].
Mischo M, Nigg C, Kiss A. Depression. [Review] [11 refs] [German]. Praxis (Bern 1994). Mar. 3. 2010;99(5):271-6. [pmid: 20205083].
Mohutsky MA, Anderson GD, Miller JW, et al. Ginkgo biloba: evaluation of CYP2C9 drug interactions in vitro and in vivo. Am J Ther. Jan. 2006;13(1):24-31. [pmid: 16428919].
Molfino A, Costelli P, Aversa Z, et al. Statins, coenzyme Q10, and cachexia: what’s the link?. Am J Cardiol. Nov. 1. 2007;100(9):1497-8. [pmid: 17950821].
Molyneux SL, Florkowski CM, Richards AM, et al. Coenzyme Q10; an adjunctive therapy for congestive heart failure?. The New Zealand medical journal. 2009;122(1305):74-79. Date of Publication: 2009 2009;(1305):74–9. [pmid: 19966871].
Moon YS, Kashyap ML. Niacin extended-release/lovastatin: combination therapy for lipid disorders. [Review] [82 refs]. Expert Opin Pharmacother. Dec. 2002;3(12):1763-71. [pmid: 12472373].
Moreyra A, Wahrburg U. Lipid lowering effects of psyllium fiber. [German]. Forschende Komplementarmedizin. 2006;13(1):56-7.
Mori TA, Bao DQ, Burke V, et al. Dietary fish as a major component of a weight-loss diet: effect on serum lipids, glucose, and insulin metabolism in overweight hypertensive subjects. Am J Clin Nutr. Nov. 1999;70(5):817-25. [pmid: 10539741].
Moroz P, Le MTQ, Norman PE. Homocysteine and abdominal aortic aneurysms. ANZ Journal of Surgery. 2007;77(5):329-332. Date of Publication: May 2007 2007;(5):329–32. [pmid: 17497968].
Morrell J. Dietary intervention with plant stanols and sterols - An opportunity to reduce heart disease risk in the UK. British Journal of Cardiology. 7(8):486+490-491+494. 2000 Date of Publication: 2000 2000;(8):486+490–491+494.
Mort JR, Kruse HR. Timing of blood pressure measurement related to caffeine consumption. [Review] [21 refs]. Ann Pharmacother. Jan. 2008;42(1):105-10. [pmid: 18094346].
Mortensen SA, Vadhanavikit S, Muratsu K, et al. Coenzyme Q10: clinical benefits with biochemical correlates suggesting a scientific breakthrough in the management of chronic heart failure. [Review] [16 refs]. Int J Tissue React. 1990;12(3):155-62. [pmid: 2276893].
Mosca L, Banka CL, Benjamin EJ, et al. Evidence-based guidelines for cardiovascular disease prevention in women: 2007 Update. Circulation. 2007;115(11):1481-1501. Date of Publication: Mar 2007 2007;(11):1481–501. [pmid: 17309915].
Mosher LR. Nicotinic acid side effects and toxicity: a review. [Review] [47 refs]. Am J Psychiatry. Mar. 1970;126(9):1290-6. [pmid: 4905018].
Mueller BA, Talbert RL. Biological mechanisms and cardiovascular effects of omega-3 fatty acids. [Review] [96 refs]. Clin Pharm. Nov. 1988;7(11):795-807. [pmid: 3058376].
Mueller PS. Symptomatic myopathy due to red yeast rice. Ann Intern Med. Sep. 2006;145(6):474-5. [pmid: 16983142].
Muir KW. New experimental and clinical data on the efficacy of pharmacological magnesium infusions in cerebral infarcts. [Review] [105 refs]. Magnes Res. Mar. 1998;11(1):43-56. [pmid: 9595548].
Aaronaes M, Atar D, Bonarjee V, et al. Treatment of congestive heart failure. [Review] [36 refs] [Norwegian]. Tidsskr Nor Laegeforen. Jan. 18. 2007;127(2):174-7. [pmid: 17237864].
Nanayakkara PW, van GC, ter Wee PM, et al. Effect of a treatment strategy consisting of pravastatin, vitamin E, and homocysteine lowering on carotid intima-media thickness, endothelial function, and renal function in patients with mild to moderate chronic kidney disease: results from the Anti-Oxidant Therapy in Chronic Renal Insufficiency (ATIC) Study. Arch Intern Med. Jun. 25. 2007;167(12):1262-70. [pmid: 17592099].
Navarro VJ, Senior JR. Drug-related hepatotoxicity. N Engl J Med. 2006;354(7):731-9. [pmid: 16481640].
Nee R, Doppenschmidt D, Donovan DJ, et al. Intravenous versus subcutaneous vitamin K1 in reversing excessive oral anticoagulation. Am J Cardiol. Jul. 6. 1999;83(2):286-8. [pmid: 10073841].
Neki NS, Singh RB, Rastogi SS. How brain influences neuro-cardiovascular dysfunction. [Review] [59 refs]. J Assoc Physicians India. Mar. 2004;52:223-30. [pmid: 15636314].
Nelson-Piercy C, Crook MA. Severe hypertriglyceridemia complicating pregnancy, management by dietary intervention and -3 fatty acid supplementation. Nutrition. 2009;25(11–12):1098-9. [pmid: 19818276].
Nelson JL, Bernstein PS, Schmidt MC, et al. Dietary modification and moderate antioxidant supplementation differentially affect serum carotenoids, antioxidant levels and markers of oxidative stress in older humans. Journal of Nutrition. 2003;133(10):3117-3123. Date of Publication: 01 Oct 2003 2003;(10):3117–23. [pmid: 14519794].
Ness AR, Chee D, Elliott P. Vitamin C and blood pressure--an overview. J Hum Hypertens. Jun. 1997;11(6):343-50. [pmid: 9249227].
NICE. Lipid modification, Clinical Guideline no. 67. National Institute for Health and Clinical Excellence. 2008.
Nishizaki M, Ashikaga T, Yamawake N, et al. Effects of glucose-induced insulin secretion on ventricular repolarization in patients with congenital long QT syndrome. Circ J. Jan. 2002;66(1):35-40. [pmid: 11999663].
Nitenberg A, Ledoux S, Attali JR, et al. Response of the coronary arteries to cold test and flow velocity increase is improved by deferoxamine but not by L-arginine in diabetic patients. [French]. Arch Mal Coeur Vaiss. Aug. 1997;90(8):1037-41. [pmid: 9404405].
Ntanios FY, Duchateau GS. A healthy diet rich in carotenoids is effective in maintaining normal blood carotenoid levels during the daily use of plant sterol-enriched spreads. [Review] [48 refs]. Int J Vitam Nutr Res. Jan. 2002;72(1):32-9. [pmid: 11887750].
Nurminen ML, Niittynen L, Korpela R, et al. Coffee, caffeine and blood pressure: a critical review. [Review] [119 refs]. Eur J Clin Nutr. Nov. 1999;53(11):831-9. [pmid: 10556993].
Nye ER. The medical treatment of atherosclerosis. [Review] [45 refs]. N Z Med J. Jul. 1967;66(419):460-4. [pmid: 4861361].
Okolicsanyi L, Lirussi F, Strazzabosco M, et al. The effect of drugs on bile flow and composition. An overview. [Review] [165 refs]. Drugs. May. 1986;31(5):430-48. [pmid: 2872047].
Okumura T, Fujioka Y, Morimoto S, et al. Eicosapentaenoic acid improves endothelial function in hypertriglyceridemic subjects despite increased lipid oxidizability. Am J Med Sci. Nov. 2002;324(5):247-53. [pmid: 12449445].
Oleszek W. Dietary phytochemicals and human health. Phytochemistry Reviews. 2002;1(2):163-166. Date of Publication: 2002 2002;(2):163–6.
Olsson AG, Or&#x00F6 L, et al. Clinical and metabolic effects of pentaerythritol tetranicotinate(Perycit)and a comparison with plain nicotinic acid. Atherosclerosis. Jan. 1974;19(1):61-73. [pmid: 4359183].
Olsson AG, Orö L, Rössner S. Clinical and metabolic effects of pentaerythritol tetranicotinate in combination with cholesolvin or clofibrate. Atherosclerosis. May. 1974;19(3):407-15. [pmid: 4364073].
Olsson AG. Laropiprant plus niacin for dyslipidemia and prevention of cardiovascular disease. [Review] [29 refs]. Expert Opin Pharmacother. Jul. 2010;11(10):1715-26. [pmid: 20518616].
Olszewer E, Carter JP. EDTA chelation therapy in chronic degenerative disease. Med Hypotheses. Sep. 1988;27(1):41-9. [pmid: 3144646].
Orimo H, Terashita K, Nakamura T, et al. Ca and atherosclerosis. J Nutr Sci Vitaminol (Tokyo). Dec. 31 Suppl. 1985:S33-36. [pmid: 3837816].
Packer M, Lee WH. Provocation of hyper- and hypokalemic sudden death during treatment with and withdrawal of converting-enzyme inhibition in severe chronic congestive heart failure. Am J Cardiol. Feb. 1. 1986;57(4):347-8. [pmid: 3004185].
Palomaki A, Malminiemi K, Malminiemi O, et al. Effects of lovastatin therapy on susceptibility of LDL to oxidation during alpha-tocopherol supplementation. Arteriosclerosis, Thrombosis, and Vascular Biology. 1999;19(6):1541-1548. Date of Publication: Jun 1999 1999;(6):1541–8.
Palomäki A, Malminiemi K, Metsä-Ketelä T. Enhanced oxidizability of ubiquinol and alpha-tocopherol during lovastatin treatment. FEBS Lett. 1997;410(2–3):254-8. [pmid: 9237640].
Palumbo B, Efthimiou Y, Stamatopoulos J, et al. Prickly pear induces upregulation of liver LDL binding in familial heterozygous hypercholesterolemia. Nucl Med Rev Cent East Eur. 2003;6(1):35-9. [pmid: 14600931].
Palumbo G, Avanzini F, Alli C, et al. Effects of vitamin E on clinic and ambulatory blood pressure in treated hypertensive patients. Collaborative Group of the Primary Prevention Project (PPP)--Hypertension study. Am J Hypertens. May. 2000;13(5 Pt 1):564-7. [pmid: 10826412].
Pan A, Yu D, Demark-Wahnefried W, et al. Meta-analysis of the effects of flaxseed interventions on blood lipids. Am J Clin Nutr. Aug. 2009;90(2):288-97. [pmid: 19515737].
Pan MZ, Guo SS, Liang XC. Effect of xianzhen tablet on Na(+)-K(+)-ATPase, Ca(2+)-Mg(2+)-ATPase, of red blood cell membrane in patients with non-insulin dependent diabetes mellitus. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine/Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. 1997;17(1):13-6.
Paoletti R, Franceschini G, Sirtori CR. Influence of bezafibrate, fenofibrate, nicotinic acid and etofibrate on plasma high-density lipoprotein levels. Am J Cardiol. Aug. 22. 1983;52(4):21B-7B. [pmid: 6351577].
Parfitt AM. The interactions of thiazide diuretics with parathyroid hormone and vitamin D. Studies in patients with hypoparathyroidism. J Clin Invest. Jul. 1972;51(7):1879-88. [pmid: 4338123].
Parkman CA. Polypha 1f40 rmacy, herbal therapies, and elders. [Review] [10 refs]. Case Manager. Jul. 2001;12(4):32-4. [pmid: 11464169].
Parness J. You’re “hot” from pumping iron?. Anesth Analg. Mar. 2009;108(3):711-3. [pmid: 19224774].
Pasternak RC, Kolman BS. Unstable myocardial ischemia after the initiation of niacin therapy. Am J Cardiol. Apr. 15. 1991;67(9):904-6. [pmid: 2011995].
Patrick L, Uzick M. Cardiovascular disease: C-reactive protein and the inflammatory disease paradigm: HMG-CoA reductase inhibitors, alpha-tocopherol, red yeast rice, and olive oil polyphenols. A review of the literature. [Review] [135 refs]. Altern Med Rev. Jun. 2001;6(3):248-71. [pmid: 11410071].
Patterson MC, Di Bisceglie AM, Higgins JJ, et al. The effect of cholesterol-lowering agents on hepatic and plasma cholesterol in Niemann-Pick disease type C. Neurology. Jan. 1993;43(1):61-4. [pmid: 8423912].
Pengo V, Banzato A, Garelli E, et al. Reversal of excessive effect of regular anticoagulation: low oral dose of phytonadione (vitamin K1) compared with warfarin discontinuation. Blood Coagul Fibrinolysis. Oct. 1993;4(5):739-41. [pmid: 8292723].
Persson CG, Andersson KE, Kjellin G. Effects of enprofylline and theophylline may show the role of adenosine. [Review] [136 refs]. Life Sci. Mar. 24. 1986;38(12):1057-72. [pmid: 3007902].
Phillips BL. Potassium-induced bowel ulceration. Br J Clin Pract Suppl. Apr. 1974;28(4):143-4. [pmid: 4841025].
Pies R. Adverse neuropsychiatric reactions to herbal and over-the-counter ‘antidepressants’. J Clin Psychiatry. 2000;61(11):815-20. [pmid: 11105733].
Pindur G, Mörsdorf S. The use of prothrombin complex concentrates in the treatment of hemorrhages induced by oral anticoagulation. [Review] [20 refs]. Thromb Res. Aug. 15. 1999;95(4 Suppl 1):S57-61. [pmid: 10499910].
Piotti LE, Ghiringhelli F, Locatelli GR. The therapeutic effect of hawthorn extract in myocardial hypoxia. [German]. Med Klin. Dec. 31. 1965;60(53):2142-5. [pmid: 5331286].
Piper CM. Very-low-protein diets in chronic renal failure: nutrient content and guidelines for supplementation. J Am Diet Assoc. Oct. 1985;85(10):1344-6. [pmid: 4045081].
Plosker GL, Wagstaff AJ. Fluvastatin: a review of its pharmacology and use in the management of hypercholesterolaemia. [Review] [130 refs]. Drugs. Mar. 1996;51(3):433-59. [pmid: 8882381].
Poli D, Antonucci E, Lombardi A, et al. Safety and effectiveness of low dose oral vitamin K1 administration in asymptomatic out-patients on warfarin or acenocoumarol with excessive anticoagulation. Haematologica. Feb. 2003;88(2):237-8. [pmid: 12604423].
Polidori MC, Cherubini A, Senin U, et al. Hyperhomocysteinemia and oxidative stress in ischemic stroke. Stroke. Jan. 2001;32(1):275-8. [pmid: 11136951].
Potter D, Burke M, Rigby P, et al. Supplemental plant sterols and stanols for serum cholesterol and cardiovascular disease [protocol for a Cochrane review]. Cochrane Database of Systematic Reviews 2008. Chichester (UK). John Wiley & Sons, Ltd. 2008;(3):3.
Pradhan B, Neopane A, Karki S, et al. Effectiveness of nicotinic acid and bezafibrate alone and in combination for reducing serum triglyceride level. Kathmandu Univ. Oct. 2005;3(4):411-4. [pmid: 16449845].
Pray WS. Challenges when recommending nonprescription products for patients with diabetes. U S Pharmacist. 2010;35(6):8-15. Date of Publication: 17 Jun 2010 2010;(6):8–15.
Pullin CH, Bonham JR, McDowell IF, et al. Vitamin C therapy ameliorates vascular endothelial dysfunction in treated patients with homocystinuria. J Inherit Metab Dis. May. 2002;25(2):107-18. [pmid: 12118525].
Rabi D, Clement F, McAlister F, et al. Effect of perioperative glucose-insulin-potassium infusions on mortality and atrial fibrillation after coronary artery bypass grafting: a systematic review and meta-analysis. [Review] [41 refs]. Can J Cardiol. Jun. 2010;26(6):178-84. [pmid: 20548978].
Rabl H, Khoschsorur G. Reduction of lipid peroxidation and reperfusion edema by anti-oxidant therapy after revascularization of an extremity. [German]. Vasa Suppl. 1992;37:60-1. [pmid: 1481103].
Raman NV, Rao CA. Magnesium sulfate as an anticonvulsant in eclampsia. Int J Gynaecol Obstet. Jun. 1995;49(3):289-98. [pmid: 9764868].
Ramsay NA, Kenny MW, Davies G, et al. Complimentary and alternative medicine use among patients starting warfarin. Br J Haematol. Sep. 2005;130(5):777-80. [pmid: 16115136].
Ramsay S. Getting the chemistry right in trials. La 1f40 ncet. May. 23. 1998;351(9115):1528. [pmid: 10326533].
Rasmussen HS. Clinical intervention studies on magnesium in myocardial infarction. Magnesium. 1989;8(5–6):316-25. [pmid: 2693849].
Rasmussen HS. Justification for magnesium therapy in acute ischaemic heart disease. Clinical and experimental studies. [Review] [235 refs]. Dan Med Bull. Mar. 1993;40(1):84-99. [pmid: 8472601].
Ray AK, Rao DB. Hypercalcemia and malignant disease in the elderly: magnesium sulphate therapy. J Am Geriatr Soc. Sep. 1974;22(9):413-5. [pmid: 4852323].
Redberg RF, Benjamin EJ, Bittner V, et al. ACCF/AHA 2009 Performance Measures for Primary Prevention of Cardiovascular Disease in Adults A Report of the American College of Cardiology Foundation/American Heart Association Task Force on Performance Measures (Writing Committee to Develop Performance Measures for Primary Prevention of Cardiovascular Disease). Journal of the American College of Cardiology. 2009;54(14):1364-1405. Date of Publication: 29 Sep 2009 2009(14):1364–405. [pmid: 19778679].
Reid IR. Effects of calcium supplementation on circulating lipids: potential pharmacoeconomic implications. [Review] [34 refs]. Drugs & Aging. 2004;21(1):7-17. [pmid: 14715041].
Reid JL. Drug therapy in hypertension: risks and benefits. [Review] [26 refs]. J Clin Hypertens (Greenwich). Jun. 1986;2(2):183-8. [pmid: 3531419].
Reidenberg MM. Statins, lack of energy and ubiquinone. Br J Clin Pharmacol. May. 2005;59(5):606-7. [pmid: 15842563].
Reisdorff EJ, Clark MR, Walters BL. Acute digitalis poisoning: the role of intravenous magnesium sulfate. [Review] [79 refs]. J Emerg Med. 1986;4(6):463-9. [pmid: 3549866].
Ren Y, Chen KJ, Ruan XM. Systematic review of randomized controlled trials on preventing and treating restenosis after percutaneous coronary intervention with Chinese medicine. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Jul. 2008;28(7):597-601. [pmid: 18822907].
Renner E, Wahländer A, Huguenin P, et al. Caffeine--an ubiquitous indicator of liver function. [German]. Schweiz Med Wochenschr. Aug. 9. Journal Suisse de Medecine. 1983;113(31–32):1074-81. [pmid: 6623026].
Repke KR. Biochemical aspects of digitalis therapy. [German]. Z Gesamte Inn Med. Feb. 1. 1971;26(3). Suppl-16. [pmid: 4254384].
Resatoglu AG, Demirturk OS, Yener N, et al. Magnesium decreases cardiac injury in patients undergoing coronary artery bypass surgery. Ann Saudi Med. Jul. 2004;24(4):259-61. [pmid: 15387489].
Resnick LM, Gupta RK, DiFabio B, et al. Intracellular ionic consequences of dietary salt loading in essential hypertension. Relation to blood pressure and effects of calcium channel blockade. J Clin Invest. Sep. 1994;94(3):1269-76. [pmid: 8083368].
Rezaieyazdi Z, Falsoleiman H, Khajehdaluee M, et al. Reduced bone density in patients on long-term warfarin. Int J Rheum Dis. Jul. 2009;12(2):130-5. [pmid: 20374330].
Richard CL, Jurgens TM. Effects of natural health products on blood pressure. [Review] [90 refs]. Ann Pharmacother. Apr. 2005;39(4):712-20. [pmid: 15741425].
Rikans LE. Drugs and nutrition in old age. [Review] [89 refs]. Life Sci. Sep. 22. 1986;39(12):1027-36. [pmid: 3528728].
Ring T. 1 alpha-hydroxy vitamin D3 and cardiovascular mortality. Nephrol Dial Transplant. Jun. 2004;19(6):1660-1. [pmid: 15150370].
Ringstrom E, Long H. Oral vitamin K for warfarin-associated coagulopathy. Ann Intern Med. Apr. 1. 2003;138(7):610-1. [pmid: 12667042].
Ringwald J, Strobel J, Eckstein R. Travel and oral anticoagulation. [Review] [47 refs]. J Travel Med. Jul. 2009;16(4):276-83. [pmid: 19674269].
Rizzon P, Iliceto S, Marangelli V. Metabolic approach to myocardial ischemia: a novel therapeutic strategy for patients with coronary artery disease?. [Review] [28 refs]. Cardiologia. Oct. 1995;40(10):717-20. [pmid: 8819732].
Roberts RJ, Leff RD. Influence of absorbable and nonabsorbable lipids and lipidlike substances on drug bioavailability. Clin Pharmacol Ther. Mar. 1989;45(3):299-304. [pmid: 2920504].
Robinson RF, Griffith JR, Nahata MC, et al. Herbal weight-loss supplement misadventures per a regional poison center. Ann Pharmacother. May. 2004;38(5):787-90. [pmid: 15044657].
Roe DA. Drug and nutrient interactions in the elderly diabetic. [Review] [29 refs]. Drug Nutr Interact. 1988;5(4):195-203. [pmid: 3071452].
Roffman DS. Special concerns of digitalis use in elderly patients. Geriatrics. 1984;39(6):97-8. [pmid: 6724308].
Rombouts EK, Rosendaal FR, van der Meer FJ. Subtherapeutic oral anticoagulant therapy: frequency and risk factors. Thromb Haemost. Mar. 2009;101(3):552-6. [pmid: 19277419].
Rosenthal J, Meurer KA, Escobar-Jimenez F, et al. Combination therapy of essential hypertension with beta receptor blockaders and diuretics. [German]. Verh Dtsch Ges Kreislaufforsch. 1977;43:223-4. [pmid: 349926].
Rosero Arenas MA, Rosero AE, Portaceli Arminana MA, et al. Usefulness of phyto-oestrogens in reduction of blood pressure: systematic review and meta-analysis (Provisional abstract). Aten Primaria. 2008;40:177-86. [pmid: 18405582].
Rourk RM, Rehman NU. Niacin. Help for your cholesterol--harm for your liver. N C Med J. Mar. 1998;59(2):87-8. [pmid: 9558894].
Rowe WS. Some aspects of diuretic therapy. Med J Aust. Mar. 22. 1975;1(12):392-4. [pmid: 1143129].
Roztocil K, Prerovsky I, Oliva I. Critical study of the therapeutic effects of phlebotropic drugs on chronic venous insufficiency. [French]. Phlebologie. Oct. 1979;32(4):395-8. [pmid: 120945].
Rozza F, de SG, Izzo R, et al. Nutraceuticals for treatment of high blood pressure values in patients with metabolic syndrome. High Blood Pressure and Cardiovascular Prevention. 2009;16(4):177-82.
Rösel H. Complications and hazards in anticoagulant therapy. [German]. Zentralbl Gynakol. Mar. 28. 1970;92(13):410-5. [pmid: 5513220].
Förstermann U. Nitric oxide and oxidative stress in vascular disease. [Review] [161 refs]. Pflugers Arch. May. 2010;459(6):923-39. [pmid: 20306272].
Rubba P. Anti-inflammatory action of statins and reduction of homocysteinemia by vitamin supplementation: interactions among strategies for cardiovascular prevention. Nutrition, metabolism, and cardiovascular diseases. 2000;10(4):173-6.
Rudnicki M, Fr⊘lich A, Fischer-Rasmussen W. Magnesium supplement in pregnancy-induced hypertension: effects on maternal and neonatal magnesium and calcium homeostasis. Miner Electrolyte Metab. 1991;17(6):399-403. [pmid: 1823392].
Ruml LA, Pak CY. Effect of potassium magnesium citrate on thiazide-induced hypokalemia and magnesium loss. Am J Kidney Dis. Jul. 1999;34(1):107-13. [pmid: 10401023].
Runkel M, Bourian M, Tegtmeier M, et al. The character of inhibition of the metabolism of 1,2-benzopyrone (coumarin) by grapefruit juice in human. Eur J Clin Pharmacol. 1997;53(3–4):265-9. [pmid: 9476043].
Ryan MP, Brady HR. The role of magnesium in the prevention and control of hypertension. [Review] [89 refs]. Ann Clin Res. Suppl 43. 1984;16:81-8. [pmid: 6398986].
Ryu KH, Han HY, Lee SY, et al. Ginkgo biloba extract enhances antiplatelet and antithrombotic effects of cilostazol without prolongation of bleeding time. Thromb Res. Jul. 2009;124(3):328-34. [pmid: 19349067].
Saheta NP. Iatrogenic cardiovascular disease (an aspect of preventive cardiology). [Review] [59 refs]. Indian Heart J. Oct. 1968;20(4):451-62. [pmid: 4392095].
Sakai T, Kamanna VS, Kashyap ML. Niacin, but not gemfibrozil, selectively increases LP-AI, a cardioprotective subfraction of HDL, in patients with low HDL cholesterol. Arterioscler Thromb Vasc Biol. Nov. 2001;21(11):1783-9. [pmid: 11701466].
Salgado BJ, Salgado JV, Dos Santos AM, et al. Effects of low-dose of niacin associated to simvastatin in the treatment of mixed dyslipidemia Salgad. Minerva Cardioangiol. Oct. 2010;58(5):531-42. [pmid: 20948500].
Salih MR, Bahari MB, Abd AY. Selected pharmacokinetic issues of the use of antiepileptic drugs and parenteral nutrition in critically ill patients. [Review]. Nutr J. 2010;9:71. [pmid: 21194458].
Saljoughian M. Coenzyme Q10: A potential cardiotonic and antioxidant. U 2011;S Pharmacist. 36(2):HS21-HS26.
Sang ZC, Wang F, Zhou Q, et al. Combined use of extended-release niacin and atorvastatin: safety and effects on lipid modification. Chin Med J. Jul. 20. 2009;122(14):1615-20. [pmid: 19719960].
Saunders RN, Azarnoff DL. Current status of drugs used to treat hyperlipoproteinemias. [Review] [25 refs]. Drug Ther. 1982:1-16. [pmid: 7049648].
Saw JT, Bahari MB, Ang HH, et al. Potential drug-herb interaction with antiplatelet/anticoagulant drugs. Complement Ther Clin Pract. Nov. 2006;12(4):236-41. [pmid: 17030294].
Saynor R. Changes in blood lipids and fibrinogen with a note on safety in a long term study on the effects of n-3 fatty acids in subjects receiving fish oil supplements and followed for seven years. Lipids. 1992;27(7):533-8. [pmid: 1453884].
Schectman G, Hiatt J. Dose-response characteristics of cholesterol-lowering drug therapies: implications for treatment. [Review] [72 refs]. Ann Intern Med. Dec. 15. 1996;125(12):990-1000. [pmid: 8967711].
Scheibe G. Comparative studies on the diuretic effect of drugs from plants. [German]. Hippokrates. Jul. 15. 1966;37(13):531-4. [pmid: 6010647].
Schellhorn W. “Calcium gout” with nephrocalcinosis due to long-term dihydrotachysterine therapy. [German]. Med Klin. Aug. 11. 1967;62(32):1232-7. [pmid: 4298777].
Schmidt LE, Dalhoff K. Food-drug interactions. [Review] [268 refs]. Drugs. 2002;62(10):1481-502. [pmid: 12093316].
Schultz HJ. Longterm treatment with anticoagulants in medical practice. [German]. Munch Med Wochenschr. May. 17. 1968;110(20):1242-8. [pmid: 4974814].
Schulze-Neick I, Penny DJ, Rigby ML, et al. L-arginine and substance P reverse the pulmonary endothelial dysfunction caused by congenital heart surgery. Circ Cardiovasc Qual Outcomes. Aug. 17. 1999;100(7):749-55. [pmid: 10449698].
Schweizer J, Hautmann C. Comparison of two dosages of ginkgo biloba extract EGb 761 in patients with peripheral arterial occlusive disease Fontaine’s stage IIb. A randomised, double-blind, multicentric clinical trial. Arzneimittelforschung. Nov. 1999;49(11):900-4. [pmid: 10604042].
Scott JR. Magnesium sulfate for mild preeclampsia. Obstet Gynecol. Feb. 2003;101(2):213. [pmid: 12576239].
Seifried HE, Anderson DE, Fisher EI, et al. A review of the interaction among dietary antioxidants and reactive oxygen species. [Review] [98 refs]. J nutr biochem. Sep. 2007;18(9):567-79. [pmid: 17360173].
Seppo L, Jauhiainen T, Nevala R, et al. Plant stanol esters in low-fat milk products lower serum total and LDL cholesterol. Eur J Nutr. Mar. 2007;46(2):111-7. [pmid: 17225918].
Shamloul R. Natural aphrodisiacs. [Review] [113 refs]. J Sex Med. Jan. 2010;7(1 Pt 1):39-49. [pmid: 19796015].
Sharma D, Varma M, Paneri S. Comparative study of Allium sativum (Garlic) and Eugenea jambolana (Jamun) as hypoglycemic and hypolipoidemic agent in Diabetes mellitus type II. Biosciences Biotechnology Research Asia. 2010;7(1):513-516. Date of Publication: June 2010 2010;(1):513–6.
Shechter M, Kaplinsky E, Rabinowitz B. Review of clinical evidence--is there a role for supplemental magnesium in acute myocardial infarction in high-risk populations (patients ineligible for thrombolysis and the elderly)?. [Review] [80 refs]. Coron Artery Dis. May. 1996;7(5):352-8. [pmid: 8866200].
Shechter M, Bairey Merz CN, Stuehlinger HG, et al. Effects of oral magnesium therapy on exercise tolerance, exercise-induced chest pain, and quality of life in patients with coronary artery disease. Am J Cardiol. Mar. 1. 2003;91(5):517-21. [pmid: 12615252].
Shen YH, Chen CX. The bioactivity of angiotensin II and the effects of related Chinese Herbs. [Review] [36 refs] [Chinese]. Zhongguo Zhong Yao Za Zhi. 431. May. 20. 28(5):394-7. [pmid: 15139119].
Sherry S. Fibrinolytic agents. [Review] [29 refs]. Dis Mon. May. 1969:3-32. [pmid: 4241828].
Shibata M, Ueshima K, Harada M, et al. Effect of magnesium sulfate pretreatment and significance of matrix metalloproteinase-1 and interleukin-6 levels in coronary reperfusion therapy for patients with acute myocardial infarction. Angiology. Jul. 1999;50(7):573-82. [pmid: 10431997].
Silver MA, Langsjoen PH, Szabo S, et al. Effect of atorvastatin on left ventricular diastolic function and ability of coenzyme Q10 to reverse that dysfunction. Am J Cardiol. Nov. 15. 2004;94(10):1306-10. [pmid: 15541254].
Simonini G, Pignone A, Generini S, et al. Emerging potentials for an antioxidant therapy as a new approach to the treatment of systemic sclerosis. [Review] [109 refs][Erratum appears in Toxicology 2001 Apr 12;162(1):69 Note: Gabriele, S [corrected to Simonini, G]; Alberto, P [corrected to Pignone, A]; Sergio, G [corrected to Generini, S]; Fernanda, F [corrected to Falcini, F]; Marco, MC [corrected to Cerinic, MM]]. Toxicology. Nov. 30. 2000;155(1–3):1-15. [pmid: 11154792].
Simons LA. Additive effect of plant sterol-ester margarine and cerivastatin in lowering low-density lipoprotein cholesterol in primary hypercholesterolemia. Am J Cardiol. Oct. 1. 2002;90(7):737-40. [pmid: 12356387].
Sinatra ST. Refractory congestive heart failure successfully managed with high dose coenzyme Q10 administration. Mol Aspects Med. Suppl. 1997;18:S299-305. [pmid: 9266540].
Singh RB, Wander GS, Rastogi A, et al. Randomized, double-blind placebo-controlled trial of coenzyme Q10 in patients with acute myocardial infarction. Cardiovasc Drugs Ther. Sep. 1998;12(4):347-53. [pmid: 9825179].
Singh RB, Niaz MA, Rastogi SS, et al. Effect of hydrosoluble coenzyme Q10 on blood pressures and insulin resistance in hypertensive patients with coronary artery disease. J Hum Hypertens. Mar. 1999;13(3):203-8. [pmid: 10204818].
Singh RB, Neki NS, Kartikey K, et al. Effect of coenzyme Q10 on risk of atherosclerosis in patients with recent myocardial infarction. Mol Cell Biochem. Apr. 2003;246(1–2):75-82. [pmid: 12841346].
Slifman NR, Obermeyer WR, Aloi BK, et al. Contamination of botanical dietary supplements by Digitalis lanata. N Engl J Med. Sep. 17. 1998;339(12):806-11. [pmid: 9738088].
Smith L, Ernst E, PaulEwings, et al. Co-ingestion of herbal medicines and warfarin. [Erratum appears in Br J Gen Pract. 2004 Jul;54(504):547]. Br J Gen Pract. Jun. 2004;54(503):439-41. [pmid: 15186565].
Smith RS, Warren DJ. Effect of nicotinic acid and dipyridamole on tissue blood flow in peripheral vascular disease. Pharmatherapeutica. 1981;2(9):597-600. [pmid: 7267676].
Smyth RM, Spark P, Armstrong N, et al. Magpie Trial in the UK: methods and additional data for women and children at 2 years following pregnancy complicated by pre-eclampsia. BMC Pregnancy Childbirth. 2009;9:15. [pmid: 19366459].
Soja AM, Mortensen SA. Treatment of chronic cardiac insufficiency with coenzyme Q10, results of meta-analysis in controlled clinical trials. [Review] [38 refs] [Danish]. Ugeskr Laeger. Dec. 1. 1997;159(49):7302-8. [pmid: 9417729].
Sola S, Mir MQ, Cheema FA, et al. Irbesartan and lipoic acid improve endothelial function and reduce markers of inflammation in the metabolic syndrome: results of the Irbesartan and Lipoic Acid in Endothelial Dysfunction (ISLAND) study. Circ Cardiovasc Qual Outcomes. Jan. 2. 2005;111(3):343-8. [pmid: 15655130].
Sole MJ, Jeejeebhoy KN. Conditioned nutritional requirements: Therapeutic relevance to heart failure. Herz. 2002;27(2):174-178. Date of Publication: 2002 2002;(2):174–8. [pmid: 12025462].
Solomon AJ, Berger AK, Trivedi KK, et al. The combination of propranolol and magnesium does not prevent postoperative atrial fibrillation. Ann Thorac Surg. Jan. 2000;69(1):126-9. [pmid: 10654500].
Sorrentino SA, Besler C, Rohrer L, et al. Endothelial-vasoprotective effects of high-density lipoprotein are impaired in patients with type 2 diabetes mellitus but are improved after extended-release niacin therapy. Circ Cardiovasc Qual Outcomes. Jan. 5. 2010;121(1):110-22. [pmid: 20026785].
Spang K. Prevention of serious arrhythmias. [Review] [13 refs] [German]. Med Welt. Apr. 3. 1971;22(14):539-42. [pmid: 4928114].
Sparks DL, Sabbagh M, Connor D, et al. Statin therapy in Alzheimer’s disease. [Review] [93 refs]. Acta Neurol Scand. Supplementum. 185. 2006:78-86. [pmid: 16866915].
Spinler SA, Hilleman DE, Cheng JW, et al. New recommendations from the 1999 American College of Cardiology/American Heart Association acute myocardial infarction guidelines. [Review] [162 refs]. Ann Pharmacother. May. 2001;35(5):589-617. [pmid: 11346067].
Spolarich AE, Andrews L. An examination of the bleeding complications associated with herbal supplements, antiplatelet and anticoagulant medications. [Review] [129 refs]. J Dent Hyg. 2007;81(3):67. [pmid: 17908423].
Spósito AC, Caramelli B, Serrano CV, et al. Effect of niacin and etofibrate association on subjects with coronary artery disease and serum high-density lipoprotein cholesterol <35 mg/dl. The American journal of cardiology. 1999;83(1):98-100. A8. [pmid: 10073791].
Squires RW, Allison TG, Gau GT, et al. Low-dose, time-release nicotinic acid: effects in selected patients with low concentrations of high-density lipoprotein cholesterol. Mayo Clin Proc. Sep. 1992;67(9):855-60. [pmid: 1434930].
Squizzato A, Dentali F, Ageno W. Treatment options for deep vein thrombosis. [Review] [41 refs]. Expert Opin Pharmacother. May. 2010;11(7):1069-75. [pmid: 20402553].
Stalenhoef AF, de GJ, Wittekoek ME, et al. The effect of concentrated n-3 fatty acids versus gemfibrozil on plasma lipoproteins, low density lipoprotein heterogeneity and oxidizability in patients with hypertriglyceridemia. Atherosclerosis. Nov. 2000;153(1):129-38. [pmid: 11058707].
Stanaszek WF, Franklin CE. Survey of potential drug interaction incidence in an outpatient clinic population. Hosp Pharm. 261. Jul. 26. 13(5):255-7. [pmid: 10236769].
Stein EA. Managing dyslipidemia in the high-risk patient. [Review] [40 refs]. Am J Cardiol. Mar. 7. 2002;89(5A):50C-7C. [pmid: 11779522].
Stein G, Sperschneider H, Koppe S. Vitamin levels in chronic renal failure and need for supplementation. Blood Purif. 1985;3(1–3):52-62. [pmid: 4096835].
Stein JH, Hadigan CM, Brown TT, et al. Prevention Strategies for Cardiovascular Disease in HIV-infected Patients. Circ Cardiovasc Qual Outcomes. 2008;118(2):e54-e60.
Stein MA, Krasowski M, Leventhal BL, et al. Behavioral and cognitive effects of methylxanthines: a meta-analysis of theophylline and caffeine (DARE structured abstract). Archives of Pediatrics and Adolescent Medicine. 1996;150:284-8. [pmid: 8603222].
Steiner M. Conservative therapy of chronic venous insufficiency. The extent of the edema-preventive effect of horse chestnut seed extract. [German]. Vasa Suppl. 1991;33:217. [pmid: 1788677].
Stella PR, Kan G. Magnesium: a promising addition to the therapy in acute myocardial infarct. [Review] [43 refs] [Dutch]. Ned Tijdschr Geneeskd. Sep. 25. 1993;137(39):1958-61. [pmid: 8413703].
Stevinson C, Ernst E. Safety of hypericum in patients with depression: A comparison with conventional antidepressants. CNS Drugs. 1999;11(2):125-32.
Stewart D, Marder VJ, Starkman S, et al. Magnesium sulfate neither potentiates nor inhibits tissue plasminogen activator-induced thrombolysis. J Thromb Haemost. Jul. 2006;4(7):1575-9. [pmid: 16839356].
Stone JM, Fisch C. Digitalis toxicity: a review. [Review] [182 refs]. J Indiana State Med Assoc. May. 1969;62(5):459-68. [pmid: 4892240].
Sun AY, Wang Q, Simonyi A, et al. Botanical phenolics and brain health. NeuroMolecular Medicine. 2008;10(4):259-274. Date of Publication: December 2008 2008;(4):259–74. [pmid: 19191039].
Superko HR, Garrett BC, King SB III, et al. Effect of combination nicotinic acid and gemfibrozil treatment on intermediate density lipoprotein, and subclasses of low density lipoprotein and high density lipoprotein in patients with combined hyperlipidemia. Am J Cardiol. Feb. 1. 2009;103(3):387-92. [pmid: 19166694].
Surawicz B. The role of potassium in cardiovascular therapy. [Review] [70 refs]. Med Clin North Am. Sep. 1968;52(5):1103-13. [pmid: 4876829].
Swaim MW, Macik BG. Vitamin K to correct overanticoagulation. Ann Intern Med. Sep. 15. 2009;151(6):432-3. [pmid: 19755375].
Szabo T, Doehner W, Anker SD. Systolic heart failure. N Engl J Med. Apr. 22. 2010;362(16):1545-6. [pmid: 20414982].
Szapary PO, Rader DJ. Pharmacological management of high triglycerides and low high-density lipoprotein cholesterol. [Review] [58 refs]. Curr Opin Pharmacol. Apr. 2001;1(2):113-20. [pmid: 11714084].
Takikawa H. Recent status of drug-induced liver injury. Hepatology Research. 2009;39(1):1-6. Date of Publication: 2009 2009;(1):1–6. [pmid: 18637144].
Tapaninen T, Neuvonen PJ, Niemi M. Grapefruit juice greatly reduces the plasma concentrations of the OATP2B1 and CYP3A4 substrate aliskiren. Clin Pharmacol Ther. Sep. 2010;88(3):339-42. [pmid: 20664534].
Task Force for Diagnosis and Treatment of Non-ST-Segment Elevation Acute Coronary Syndromes of European Society of Cardiology. Bassand JP, Hamm CW, et al. Guidelines for the diagnosis and treatment of non-ST-segment elevation acute coronary syndromes. [514 refs]. Eur Heart J. Jul. 2007;28(13):1598-660. [pmid: 17569677].
Taylor AJ, Sullenberger LE, Lee HJ, et al. Arterial Biology for the Investigation of the Treatment Effects of Reducing Cholesterol (ARBITER) 2: a double-blind, placebo-controlled study of extended-release niacin on atherosclerosis progression in secondary prevention patients treated with statins. Circ Cardiovasc Qual Outcomes. 2004;110(23):3512-7.
Taylor AJ, Lee HJ, Sullenberger LE. The effect of 24 months of combination statin and extended-release niacin on carotid intima-media thickness: ARBITER 3. Curr Med Res Opin. Nov. 2006;22(11):2243-50. [pmid: 17076985].
Taylor CT, Chester EA, Byrd DC, et al. Vitamin K to reverse excessive anticoagulation: a review of the literature. [Review] [31 refs]. Pharmacotherapy. Dec. 1999;19(12):1415-25. [pmid: 10600090].
Teo KK, Yusuf S, Collins R, et al. Effects of intravenous magnesium in suspected acute myocardial infarction: overview of randomised trials. BMJ. Dec. 14. 1991;303(6816):1499-503. [pmid: 1838289].
Terrie YC. Nutritional supplements and cardiovascular health. Pharmacy Times. 2010;76(12).
Terrone DA, Rinehart BK, Kimmel ES, et al. A prospective, randomized, controlled trial of high and low maintenance doses of magnesium sulfate for acute tocolysis. Am J Obstet Gynecol. Jun. 2000;182(6):1477-82. [pmid: 10871468].
Thakkar RB, Kashyap ML, Lewin AJ, et al. Acetylsalicylic acid reduces niacin extended-release-induced flushing in patients with dyslipidemia. Am J Cardiovasc Drugs. 2009;9(2):69-79. [pmid: 19331435].
Theuwissen E, Plat J, van der Kallen CJ, et al. Plant stanol supplementation decreases serum triacylglycerols in subjects with overt hypertriglyceridemia. Lipids. Dec. 2009;44(12):1131-40. [pmid: 19904567].
Thoenes M, Oguchi A, Nagamia S, et al. The effects of extended-release niacin on carotid intimal media thickness, endothelial function and inflammatory markers in patients with the metaboli 180 c syndrome. Int J Clin Pract. Nov. 2007;61(11):1942-8. [pmid: 17935553].
Thomas MC, Johnston CI. Valsartan. J Drug Eval. 2004;2(3):67-101.
Thompson Coon JS, Ernst E. Herbs for serum cholesterol reduction: a systematic review (DARE structured abstract). J Fam Pract. 2003;52:468-78. [pmid: 12791229].
Thögersen AM, Jansson JH, Wester PO. Magnesium therapy, fibrinolytic parameters and von Willebrand factor in acute myocardial infarction. Int J Cardiol. 1996;56(1):53-9. [pmid: 8891805].
Tian J, Yin J, Liu H, et al. Jian Nao Ning for treatment of memory impairment in patients with mild or moderate multi-infarct dementia. J Tradit Chin Med. Dec. 2002;22(4):247-51. [pmid: 16579082].
Timmer JR, van der Horst IC, Ottervanger JP, et al. Glucose-insulin-potassium infusion as adjunctive therapy in myocardial infarction: current evidence and potential mechanisms. Ital Heart J. Oct. 2004;5(10):727-31. [pmid: 15626267].
Tolman KG. Defining patient risks from expanded preventive therapies. [Review] [22 refs]. Am J Cardiol. Jun. 22. 2000;85(12A):15E-9E. [pmid: 10858489].
Toth PP, Zarotsky V, Sullivan JM, et al. Niacin and fibrate use among patients with high triglycerides and low high-density lipoprotein cholesterol. Curr Med Res Opin. Jun. 2009;25(6):1355-63. [pmid: 19425901].
Tränkmann P, Thiele R, Winnefeld K, et al. Effect of administration of selenium and vitamin E on heart failure and ventricular arrhythmias in patients with acute myocardial infarct. Medizinische Klinik (Munich, Germany : 1983). 1999;94(Suppl 3):78-80.
Trekova NA, Andrianova MI, Tolstova IA, et al. Use of a potassium and magnesium asparaginate solution to maintain the balance of potassium and magnesium during cardiosurgical interventions under extracorporeal circulation. [Russian]. Anesteziol Reanimatol. Sep. 2008;(5):17-21. [pmid: 19105253].
Turgut F, Kanbay M, Metin MR, et al. Magnesium supplementation helps to improve carotid intima media thickness in patients on hemodialysis. Int Urol Nephrol. 2008;40(4):1075-82. [pmid: 18568412].
Ulbricht C, Chao W, Costa D, et al. Clinical evidence of herb-drug interactions: a systematic review by the natural standard research collaboration. Curr Drug Metab. 2008;9(10):1063-120. [pmid: 19075623].
Uygur BO, Kalkay MN, Oskay BE, et al. St. John’s wort (Hypericum perforatum) and warfarin: Dangerous liaisons!. Turk J Gastroenterol. Feb. 2011;22(1):115. [pmid: 21480130].
Vacek JL, Dittmeier G, Chiarelli T, et al. Comparison of lovastatin (20 mg) and nicotinic acid (1.2 g) with either drug alone for type II hyperlipoproteinemia. Ameri 1f40 can Journal of Cardiology. Jul. 15. 1995;76(3):182-4. [pmid: 7611158].
Valdés G, Vio CP, Montero J, et al. Potassium supplementation lowers blood pressure and increases urinary kallikrein in essential hypertensives. J Hum Hypertens. Apr. 1991;5(2):91-6. [pmid: 2072372].
van de Water JM, van den Bergh WM, Hoff RG, et al. Hypocalcaemia may reduce the beneficial effect of magnesium treatment in aneurysmal subarachnoid haemorrhage. Magnes Res. Jun. 2007;20(2):130-5. [pmid: 18062586].
van den Bergh WM, Algra A, Rinkel GJ, et al. Magnesium and aspirin treatment in patients with subarachnoid haemorrhage. Comparison of effects after endovascular and neurosurgical aneurysm occlusion. J Neurol. Feb. 2009;256(2):213-6. [pmid: 19169852].
van Doormaal JJ, Idema IG, Muskiet FA, et al. Effects of short-term high dose intake of evening primrose oil on plasma and cellular fatty acid compositions, alpha-tocopherol levels, and erythropoiesis in normal and type 1 (insulin-dependent) diabetic men. Diabe 1f40 tologia. Aug. 1988;31(8):576-84. [pmid: 3065111].
van Tits LJ, de WF, Hak-Lemmers HL, et al. Effects of alpha-tocopherol on superoxide production and plasma intercellular adhesion molecule-1 and antibodies to oxidized LDL in chronic smokers. Free Radic Biol Med. May. 15. 2001;30(10):1122-9. [pmid: 11369502].
Van DM, Stalenhoef AFH, Wittekoek J, et al. Efficacy of concentrated n-3 fatty acids in hypertriglyceridaemia: A comparison with gemfibrozil. Clin Drug Invest. 2001;21(3):175-81.
Vandenberg BF, Robinson J. Management of the patient with statin intolerance. [Review]. Curr Atheroscler Rep. Jan. 2010;12(1):48-57. [pmid: 20425271].
Vaturi M, Strasberg B. Magnesium in the management of acute myocardial infarction--has it proved beneficial?. [Review] [9 refs]. Int J Cardiol. Dec. 1. 1999;71(3):217-8. [pmid: 10636526].
Vega GL, Grundy SM. Effect of statins on metabolism of apo-B-containing lipoproteins in hypertriglyceridemic men. [Review] [26 refs]. Am J Cardiol. Feb. 26. 1998;81(4A):36B-42B. [pmid: 9462603].
Ventura HO, Milani RV, Lavie CJ, et al. Cyclosporine-induced hypertension. Efficacy of omega-3 fatty acids in patients after cardiac transplantation. Circ Cardiovasc Qual Outcomes. Nov. 1993;88(5 Pt 2):II281-285. [pmid: 8222166].
Vester EG. Clinico-electrophysiologic effects of magnesium, especially in supraventricular tachycardia. [Review] [33 refs] [German]. Herz. Jun. Suppl 1. 1997;22:40-50. [pmid: 9333591].
Vinson J, Cai X, Al KH. A natural, multi-mechanistic supplement approach for improving cardiovascular risk factors. Journal of Complementary and Integrative Medicine. 2007;4(1). Article Number: 4 Date of Publication: 2007 2007;(1).
Virtanen SM, Aro A. Dietary factors in the aetiology of diabetes. [Review] [132 refs]. Ann Med. Dec. 1994;26(6):469-78. [pmid: 7695875].
Vlassara H, Cai W, Crandall J, et al. Inflammatory mediators are induced by dietary glycotoxins, a major risk factor for diabetic angiopathy. Proc Natl Acad Sci U S A. 2002;99(24):15596-601. [pmid: 12429856].
Voelker R. Cardiac patients’ herbal supplement use deserves more careful investigation. JAMA. Mar. 3. 2010;303(9):824. [pmid: 20197523].
Vogt A, Kassner U, Hostalek U, et al. Correction of low HDL cholesterol to reduce cardiovascular risk: practical considerations relating to the therapeutic use of prolonged-release nicotinic acid (Niaspan). [Review] [67 refs]. Int J Clin Pract. Nov. 2007;61(11):1914-21. [pmid: 17935550].
Vosper H. Niacin: a re-emerging pharmaceutical for the treatment of dyslipidaemia. [Review] [136 refs]. Br J Pharmacol. Sep. 2009;158(2):429-41. [pmid: 19627285].
Wadelius M, Chen LY, Lindh JD, et al. The largest prospective warfarin-treated cohort supports genetic forecasting. Blood. Jan. 22. 2009;113(4):784-92. [pmid: 18574025].
Walker WG. Indications and contraindications for diuretic therapy. Ann New York Acad Sci. Nov. 22. 1966;139(2):481-96. [pmid: 5230289].
Wang E, Wylie-Rosett J. Review of selected Chinese herbal medicines in the treatment of type 2 diabetes. [Review] [32 refs]. Diabetes Educ. Jul. 2008;34(4):645-54. [pmid: 18669806].
Wang L, Xiong ZY, Wang G. Systematic assessment on randomized controlled trials for treatment of stable angina pectoris by compound salvia pellet. [Review] [26 refs] [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Jun. 2004;24(6):500-4. [pmid: 15250200].
Wang Q, Wu T, Chen X, et al. Puerarin injection for unstable angina pectoris [Cochrane review]. Cochrane Database of Systematic Reviews 2006. Chichester (UK). John Wiley & Sons, Ltd. 2006;(3):3.
Wang ZL, Qian SM, Zhang HM. Effect of Xin’anning Nasal Drop in treating coronary heart disease with unstable angina pectoris. Chin J Integr Med. 2006;12(4):301-5. [pmid: 17361529].
Warnholtz A, Wild P, Ostad MA, et al. Effects of oral niacin on endothelial dysfunction in patients with coronary artery disease: results of the randomized, double-blind, placebo-controlled INEF study. Atherosclerosis. May. 2009;204(1):216-21. [pmid: 18822413].
Weber WW, Hein DW. N-acetylation pharmacogenetics. [Review] [467 refs]. Pharmacol Rev. Mar. 1985;37(1):25-79. [pmid: 2860675].
Weibert RT, Le DT, Kayser SR, et al. Correction of excessive anticoagulation with low-dose oral vitamin K1. Ann Intern Med. Jun. 15. 1997;126(12):959-62. [pmid: 9182473].
Weideman R, Patel AP. Oral vitamin K for warfarin-associated coagulopathy. Ann Intern Med. Apr. 1. 2003;138(7):610. [pmid: 12667043].
Weitberg AB. Effect of nicotinic acid supplementation in vivo on oxygen radical-induced genetic damage in human lymphocytes. Mutat Res. Aug. 1989;216(4):197-201. [pmid: 2761560].
Weitz JI. New oral anticoagulants in development. [Review] [80 refs]. Thromb Haemost. Jan. 2010;103(1):62-70. [pmid: 20062934].
Weng L-C, Yeh W-T, Bai C-H, et al. Is ischemic stroke risk related to folate status or other nutrients correlated with folate intake?. Stroke. 2008;39(12):3152-3158. Date of Publication: 01 Dec 2008 2008;(12):3152–8. [pmid: 18988909].
Werbeloff S. Hypericum-drug interactions and implications for other hepatic herbs. Australian Journal of Medical Herbalism. 2001;13(2):59-69.
West SG. Effect of diet on vascular reactivity: an emerging marker for vascular risk. [Review] [65 refs]. Curr Atheroscler Rep. Nov. 2001;3(6):446-55. [pmid: 11602064].
Westphal S, Borucki K, Luley C, et al. Treatment with niacin lowers ADMA. Atherosclerosis. Feb. 2006;184(2):448-50. [pmid: 16376893].
Westphal S, Borucki K, Taneva E, et al. Extended-release niacin raises adiponectin and leptin. Atherosclerosis. Aug. 2007;193(2):361-5. [pmid: 16887123].
Wheatley D. Side-effects are no problem with St John’s wort in depression. Prim Care Psychiatry. 2002;8(1):31-3.
Whight C, Morgan T, Carney S, et al. Diuretics, cardiac failure and potassium depletion: a rational approach. Med J Aust. Dec. 7. 1974;2(23):831-3. [pmid: 4217884].
Whitlock RP, Crowther MA, Warkentin TE, et al. Warfarin cessation before cardiopulmonary bypass: lessons learned from a randomized controlled trial of oral vitamin K. Ann Thorac Surg. Jul. 2007;84(1):103-8. [pmid: 17588394].
Wiedermann CJ. Magnesium in acute myocardial infarction?. Wien Klin Wochenschr. Oct. 31. 2002;114(19–20):817-8. [pmid: 12503471].
Willgeroth F, Rummel W. Drugs in pregnancy and lactation (ending). [German]. Fortschr Med Orig. Dec. 20. 1979;97(48):2226-34. [pmid: 535871].
Williams L, Bradford J. Should I take coenzyme Q10 with a statin?. JAAPA. Dec. 2006;19(12):61-2. [pmid: 17243263].
Willis AL, Smith DL. Eicosanoid aspects of atherosclerosis. [Review] [66 refs]. Prog Clin Biol Res. 1989;301:73-84. [pmid: 2552468].
Willis AL, Smith DL. Therapeutic impact of eicosanoids in atherosclerotic disease. [Review] [348 refs]. Eicosanoids. 1989;2(2):69-99. [pmid: 2697316].
Witte KKA, Nikitin NP, Parker AC, et al. The effect of micronutrient supplementation on quality-of-life and left ventricular function in elderly patients with chronic heart failure. European Heart Journal. 2005;26(21):2238-2244. Date of Publication: Nov 2005 2005;(21):2238–44. [pmid: 16081469].
Witte KKA, Clark AL. Marine polyunsaturated fatty acids in heart failure are the theoretical benefits matched by the clinical data?. Pol Arch Med Wewn. 2009;119(3):162-9. [pmid: 19514646].
Wittenborn JR. A search for responders to niacin supplementation. Arch Gen Psychiatry. Oct. 1974;31(4):547-52. [pmid: 4607587].
Wolf R, Orion E, Matz H, et al. Miscellaneous treatments, II: niacin and heparin: unapproved uses, dosages, or indications. [Review] [113 refs]. Clin Dermatol. Sep. 2002;20(5):547-57. [pmid: 12435525].
Wollert HG, Grossmann H, Eckel L. Magnesium sulfate prevents atrial tachyarrhythmias after cardiac and non-cardiac surgery--what is the common mechanism?. Thorac Cardiovasc Surg. Aug. 1997;45(4):213-4. [pmid: 9323829].
Wong GK, Kwok R, Tang K, et al. Effects of magnesium sulfate infusion on cerebral perfusion in patients after aneurysmal SAH. Acta Neurochir Suppl. 2010;106:133-5. [pmid: 19812935].
Wood MJ, Stewart RL, Merry H, et al. Use of complementary and alternative medical therapies in patients with cardiovascular disease. Am Heart J. May. 2003;145(5):806-12. [pmid: 12766736].
Woods K, Douketis JD, Kathirgamanathan K, et al. Low-dose oral vitamin K to normalize the international normalized ratio prior to surgery in patients who require temporary interruption of warfarin. J Thromb Thrombolysis. Oct. 2007;24(2):93-7. [pmid: 17380255].
Woods KL. Review of research methodology used in clinical trials of magnesium and myocardial infarction--why does controversy persist despite ISIS-4?. [Review] [24 refs]. Coron Artery Dis. May. 1996;7(5):348-51. [pmid: 8866199].
Woolf AD. Safety evaluation and adverse events monitoring by poison control centers: A framework for herbs & dietary supplements. Clin Toxicol. 2006;44(5):617-22.
Wu KK. Novel mechanisms of aspirin pharmacologic actions: a model for studying herbal natural products. Thromb Res. 2005;117(1–2):61-4. [pmid: 16045971].
Wu Y, Li S, Cui W, et al. Ginkgo biloba extract improves coronary blood flow in patients with coronary artery disease: role of endothelium-dependent vasodilation. Planta Med. Jun. 2007;73(7):624-8. [pmid: 17564952].
Wu YZ, Li SQ, Zu XG, et al. Ginkgo biloba extract improves coronary artery circulation in patients with coronary artery disease: contribution of plasma nitric oxide and endothelin-1. PHYTOTHER RES. Jun. 2008;22(6):734-9. [pmid: 18446847].
Yam D, Friedman J, Bott-Kanner G, et al. Omega-3 fatty acids reduce hyperlipidaemia, hyperinsulinaemia and hypertension in cardiovascular patients. Journal of Clinical and Basic Cardiology. 2002;5(3):229-31.
Yilmaz A, Arikan O, Dokmetas S. Effects of statins on bone mineral density. Saudi Med J. Sep. 2006;27(9):1433-5. [pmid: 16951794].
Yin J, Zhang H, Ye J. Traditional chinese medicine in treatment of metabolic syndrome. [Review] [194 refs]. Endocr Metab Immune Disord Drug Targets. Jun. 2008;8(2):99-111. [pmid: 18537696].
Yiu KH, Siu CW, Jim MH, et al. Comparison of the efficacy and safety profiles of intravenous vitamin K and fresh frozen plasma as treatment of warfarin-related over-anticoagulation in patients with mechanical heart valves. Am J Cardiol. Feb. 1. 2006;97(3):409-11. [pmid: 16442406].
Yokoyama M, Origasa H. Effects of eicosapentaenoic acid on cardiovascular events in Japanese patients with hypercholesterolemia: rationale, design, and baseline characteristics of the Japan. EPA Lipid Intervention Study (JELIS). Am Heart J. Oct. 2003;146(4):613-20. [pmid: 14564313].
Yoshiji H, Noguchi R, Toyohara M, et al. Combination of vitamin K2 and angiotensin-converting enzyme inhibitor ameliorates cumulative recurrence of hepatocellular carcinoma. J Hepatol. Aug. 2009;51(2):315-21. [pmid: 19501932].
Yu XD, Zhou WQ, Cui L. Hypotensive action of luohuo capsule and its effect on plasma adrenal medullin and tissue factor pathway inhibitor. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Sep. 2003;23(9):668-72. [pmid: 14571614].
Yuan J, Guo W, Yang B, et al. 116 cases of coronary angina pectoris treated with powder composed of radix ginseng, radix notoginseng and succinum. J Tradit Chin Med. Mar. 1997;17(1):14-7. [pmid: 10437237].
Yusuf S, Flather M. Magnesium in acute myocardial infarction. BMJ. Mar. 25. 1995;310(6982):751-2. [pmid: 7711567].
Zambon A, Deeb SS, Brown BG, et al. Common hepatic lipase g 1f40 ene promoter variant determines clinical response to intensive lipid-lowering treatment. Circ Cardiovasc Qual Outcomes. Feb. 13. 2001;103(6):792-8. [pmid: 11171785].
Zand J, Lanza F, Garg HK, et al. All-natural nitrite and nitrate containing dietary supplement promotes nitric oxide production and reduces triglycerides in humans. Nutr Res. Apr. 2011;31(4):262-9. [pmid: 21530799].
Zellner C, Boyle A, Yeghiazarians Y. Magnesium sulfate for transradial cardiac catheterization: teaching an old dog new tricks. J Invasive Cardiol. Oct. 2008;20(10):543-4. [pmid: 18829999].
Zemel MB. Calcium modulation of hypertension and obesity: mechanisms and implications. [Review] [36 refs]. J Am Coll Nutr. Oct. 2001;20(5 Suppl):428S-35S. [pmid: 11603653].
Zhang J-H, Shang H-C, Zheng W-K, et al. Systematic review on the compatibility of shuanghuanglian injection combined with western medical injections. Chin J Evid -Based Med. 2010;10(2):148-55.
Zhao XQ, Brown BG, Hillger L, et al. Effects of intensive lipid-lowering therapy on the coronary arteries of asymptomatic subjects with elevated apolipoprotein B. Circ Cardiovasc Qual Outcomes. Dec. 1993;88(6):2744-53. [pmid: 8252687].
Zhou YM, Huang ZQ, Hu MH, et al. Clinical study on the effect of Shengxueling on idiopathic thrombocytopenic purpura. Chin J Integr Med. Mar. 2005;11(1):60-4. [pmid: 15975312].
Zhu ZZ, Xiong MQ, Lin AZ. Effect of sanhuang jiangtang recipe on insulin peripheral resistance in type II diabetics. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine/Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban. 1997;17(10):590-3.
Zoeller JL. Complementing drug therapy. Drug Benefit Trends. 2008;20(6):195. Date of Publication: June 2008 2008;(6):195.
Zweifler AJ, Thompson GR. Correction of thiazide hyperuricemia by potassium chloride and ammonium chloride. Arthritis Rheum. Dec. 1965;8(6):1134-44. [pmid: 5884822].

## Not Relevant Population

Eligibility: Adults taking one or more specific cardiovascular drugs or class of drugs commonly used in the outpatient setting

Coumadin and ginseng: a potentially dangerous combination. Health News. Nov. 2004;10(11):11. [pmid: 15655860].
Summaries for patients. Targeting cholesterol treatment toward increasing high-density lipoprotein levels. [Original report in Ann Intern Med. 2005 Jan 18;142(2):95–104; PMID:15657157]. Ann Intern Med. Jan. 18. 2005;142(2):I46. [pmid: 15657152].
Ginkgo and Alzheimer’s disease: little or no different from placebo. Prescrire Int. Oct. 2007;16(91):205-7. [pmid: 17926840].
Summaries for patients. Red yeast rice to treat cholesterol problems in patients who cannot tolerate statin therapy because of muscle pain. [Original report in Ann Intern Med. 2009 Jun 16;150(12):830–9, W147–9; PMID:19528562]. Ann Intern Med. Jun. 16. 2009;150(12):I28. [pmid: 19528545].
Research to investigate link between supplements and lung disease. Australian Journal of Pharmacy. 2009;90(1072):20. Date of Publication: September 2009 2009;(1072):20.
Abad MJ, Bedoya LM, Bermejo P. An update on drug interactions with the herbal medicine Ginkgo biloba. Curr Drug Metab. Feb. 2010;11(2):171-81. [pmid: 20359286].
Ackermann RT, Mulrow CD, Ramirez G, et al. Garlic shows promise for improving some cardiovascular risk factors. [Review] [77 refs]. Arch Intern Med. Mar. 26. 2001;161(6):813-24. [pmid: 11268223].
Agbabiaka TB, Pittler MH, Wider B, et al. Serenoa repens (Saw Palmetto): A systematic review of adverse events. Drug Saf. 2009;32(8):637-47. [pmid: 19591529].
Alam S, Johnson AG. A meta-analysis of randomised controlled trials (RCT) among healthy normotensive and essential hypertensive elderly patients to determine the effect of high salt (NaCl) diet of blood pressure. J Hum Hypertens. Jun. 1999;13(6):367-74. [pmid: 10408586].
Alessandri C, Pignatelli P, Loffredo L, et al. Alpha-linolenic acid-rich wheat germ oil decreases oxidative stress and CD40 ligand in patients with mild hypercholesterolemia. Arteriosclerosis, thrombosis, and vascular biology. 2006;26(11):2577-8.
Alghamdi AA, Al-Radi OO, Latter DA. Intravenous magnesium for prevention of atrial fibrillation after coronary artery bypass surgery: a systematic review and meta-analysis. [Review] [43 refs]. J Card Surg. May. 2005;20(3):293-9. [pmid: 15854101].
Alkhenizan AH, Al-Omran MA. The role of vitamin E in the prevention of coronary events and stroke. Meta-analysis of randomized controlled trials. Saudi Med J. Dec. 2004;25(12):1808-14. [pmid: 15711645].
Allender PS, Cutler JA, Follmann D, et al. Dietary calcium and blood pressure: a meta-analysis of randomized clinical trials. Ann Intern Med. May. 1. 1996;124(9):825-31. [pmid: 8610952].
Allman MA, Pena MM, Pang D. Supplementation with flaxseed oil versus sunflowerseed oil in healthy young men consuming a low fat diet: effects on platelet composition and function. Eur J Clin Nutr. Mar. 1995;49(3):169-78. [pmid: 7774533].
Anderson JW, Allgood LD, Lawrence A, et al. Cholesterol-lowering effects of psyllium intake adjunctive to diet therapy in men and women with hypercholesterolemia: meta-analysis of 8 controlled trials. Am J Clin Nutr. Feb. 2000;71(2):472-9. [pmid: 10648260].
Anderson TW. Vitamin E in angina pectoris. Can Med Assoc J. Feb. 16. 1974;110(4):401-6. [pmid: 4204790].
Anderson TW, Reid DB. A double-blind trial of vitamin E in angina pectoris. Am J Clin Nutr. Oct. 1974;27(10):1174-8. [pmid: 4214473].
Andreassen AK, Hartmann A, Offstad J, et al. Hypertension prophylaxis with omega-3 fatty acids in heart transplant recipients. J Am Coll Cardiol. May. 1997;29(6):1324-31. [pmid: 9137231].
Andrioli G, Carletto A, Guarini P, et al. Differential effects of dietary supplementation with fish oil or soy lecithin on human platelet adhesion. Thromb Haemost. Nov. 1999;82(5):1522-7. [pmid: 10595648].
Antman EM. Magnesium in acute myocardial infarction: overview of available evidence. [Review] [53 refs]. Am Heart J. Aug. 1996;132(2 Pt 2 Su):487-95. [pmid: 8694009].
Antman EM, Seelig MS, Fleischmann K, et al. Magnesium in acute myocardial infarction: scientific, statistical, and economic rationale for its use. [Review] [55 refs]. Cardiovasc Drugs Ther. Jul. 1996;10(3):297-301. [pmid: 8877070].
Macao LB, Wilhelm FD, Pedrosa RC, et al. Antioxidant therapy attenuates oxidative stress in chronic cardiopathy associated with Chagas’ disease. Int J Cardiol. Dec. 15. 2007;123(1):43-9. [pmid: 17328977].
Arató E, Kürthy M, Sínay L, et al. Effect of vitamin E on reperfusion injuries during reconstructive vascular operations on lower limbs. Clinical hemorheology and microcirculation. 2010;44(2):125-36. [pmid: 20203367].
Arató E, Kürthy M, Sínay L, et al. Effect of vitamin E on reperfusion injuries during reconstructive vascular operations on lower limbs. Clinical hemorheology and microcirculation. 2010;44(2):125-36. [pmid: 20203367].
Arruzazabala ML, M&#x00E1 sR, et al. Effect of policosanol on platelet aggregation in type II hypercholesterolemic patients. Int J Tissue React. 1998;20(4):119-24. [pmid: 10093795].
Ascherio A, Rimm EB, Hern&#x00E1, et al. Intake of potassium, magnesium, calcium, and fiber and risk of stroke among US men. Circ Cardiovasc Qual Outcomes. Sep. 22. 1998;98(12):1198-204. [pmid: 9743511].
Asplund K. Antioxidant vitamins in the prevention of cardiovascular disease: a systematic review. J Intern Med. May. 2002;251(5):372-92. [pmid: 11982737].
Assanelli D, Bonanome A, Pezzini A, et al. Folic acid and vitamin E supplementation effects on homocysteinemia, endothelial function and plasma antioxidant capacity in young myocardial-infarction patients. Pharmacological research : the official journal of the Italian Pharmacological Society. 2004;49(1):79-84. [pmid: 14597156].
Authors. Nagyov&#x00E1 A, Mongiellov&#x00E1, et al. Serum ex vivo lipoprotein oxidizability in patients with ischemic heart disease supplemented with vitamin E. Physiol Res 1f40. 2002;51(5):457-64. [pmid: 12470198].
Autier P, Gandini S. Vitamin D supplementation and total mortality: a meta-analysis of randomized controlled trials. Arch Intern Med. Sep. 10. 2007;167(16):1730-7. [pmid: 17846391].
Axelrod L, Camuso J, Williams E, et al. Effects of a small quantity of omega-3 fatty acids on cardiovasc 1f40 ular risk factors in NIDDM. A randomized, prospective, double-blind, controlled study. Diabetes Care. Jan. 1994;17(1):37-44. [pmid: 8112187].
Aydin H, Deyneli O, Yavuz D, et al. Short-term oral magnesium supplementation suppresses bone turnover in postmenopausal osteoporotic women. Biol Trace Elem Res. Feb. 2010;133(2):136-43. [pmid: 19488681].
Azen SP, Qian D, Mack WJ, et al. Effect of supplementary antioxidant vitamin intake on carotid arterial wall intima-media thickness in a controlled clinical trial of cholesterol lowering. Circ Cardiovasc Qual Outcomes. Nov. 15. 1996;94(10):2369-72. [pmid: 8921775].
Azuma J, Sawamura A, Awata N. Usefulness of taurine in chronic congestive heart failure and its prospective application. Jpn Circ J. Jan. 1992;56(1):95-9. [pmid: 1538580].
Bachour G, Bender F, Wessels F, et al. Oral treatment of hypertension using the calcium-antagonist verapamil. [German]. Verh Dtsch Ges Inn Med. Pt 2. 1976;82:1334-6. [pmid: 801084].
Bairati I, Roy L, Meyer F. Effects of a fish oil 1f40 supplement on blood pressure and serum lipids in patients treated for coronary artery disease. Can J Cardiol. Jan. 1992;8(1):41-6. [pmid: 1617510].
Baker EM, Hodges RE, Hood J, et al. Metabolism of ascorbic-1-14C acid in experimental human scurvy. Am J Clin Nutr. May. 1969;22(5):549-58. [pmid: 4891320].
Baker WL, Baker EL, Coleman CI. The effect of plant sterols or stanols on lipid parameters in patients with type 2 diabetes: a meta-analysis. Diabetes Res Clin Pract. May. 2009;84(2):e33-e37. [pmid: 19243852].
Balk E, Chung M, Chew P, et al. Effects of soy on health outcomes. Evid Rep Technol Assess (Summ). Aug. 2005;(126):1-8. [pmid: 16194125].
Balk EM, Tatsioni A, Lichtenstein AH, et al. Effect of chromium supplementation on glucose metabolism and lipids: a systematic review of randomized controlled trials. Diabetes Care. Aug. 2007;30(8):2154-63. [pmid: 17519436].
Bao DQ, Mori TA, Burke V, et al. Effects of dietary fish and weight reduction on ambulatory blood pressure in overweight hypertensives. Hypertension. Oct. 1998;32(4):710-7. [pmid: 9774368].
Barceló-Coblijn G, Murphy EJ, Othman R, et al. Flaxseed oil and fish-oil capsule consumption alters human red blood cell n-3 fatty acid composition: a multiple-dosing trial comparing 2 sources of n-3 fatty acid. The American journal of clinical nutrition. 2008;88(3):801-9. [pmid: 18779299].
Barnard K, Colon-Emeric C. Extraskeletal effects of vitamin D in older adults: cardiovascular disease, mortality, mood, and cognition (Provisional abstract). Am J Geriatr Pharmacother. 2010:4-33. [pmid: 20226390].
Barnard K, Colon-Emeric C. Extraskeletal effects of vitamin D in older adults: cardiovascular disease, mortality, mood, and cognition. [Review] [81 refs]. Am J Geriatr Pharmacother. Feb. 2010;8(1):4-33. [pmid: 20226390].
Barrett B, Kiefer D, Rabago D. Assessing the risks and benefits of herbal medicine: an overview of scientific evidence. Altern Ther Health Med. 1999;5(4):40-9. [pmid: 10394673].
Baumann KH, Hessel F, Larass I, et al. Dietary omega-3, omega-6, and omega-9 unsaturated fatty acids and growth factor and cytokine gene expression in unstimulated and stimulated monocytes. A randomized volunteer study. Arterioscler Thromb Vasc Biol. Jan. 1999;19(1):59-66. [pmid: 9888867].
Bazzano LA, Reynolds K, Holder KN, et al. Effect of folic acid supplementation on risk of cardiovascular diseases: a meta-analysis of randomized controlled trials. JAMA. Dec. 13. 2006;296(22):2720-6. [pmid: 17164458].
Becker DJ, Gordon RY, Halbert SC, et al. Red yeast rice for dyslipidemia in statin-intolerant patients: a randomized trial. [Summary for patients in Ann Intern Med. 2009 Jun 16;150(12):I28; PMID:19528545]. Ann Intern Med. 2009;150(12):830-9. [pmid: 19528562].
Becker DJ, Gordon RY, Halbert SC, et al. Red yeast rice for dyslipidemia in statin-intolerant patients: a randomized trial. Ann Intern Med. 2009;150(12):830-9. W147. [pmid: 19528562].
Beckert BW, Concannon MJ, Henry SL, et al. The effect of herbal medicines on platelet function: an in vivo experiment and review of the literature. [Review] [45 refs]. Pla 1f40 st Reconstr Surg. Dec. 2007;120(7):2044-50. [pmid: 18090773].
Belardinelli R, Mucaj A, Lacalaprice F, et al. Coenzyme Q10 improves contractility of dysfunctional myocardium in chronic heart failure. Biofactors. 2005;25(1–4):137-45. [pmid: 16873938].
Belfort MA, Moise KJ Jr. Effect of magnesium sulfate on maternal brain blood flow in preeclampsia: a randomized, placebo-controlled study. Am J Obstet Gynecol. Sep. 1992;167(3):661-6. [pmid: 1530019].
Bereczki D, Fekete I. Vinpocetine for acute ischaemic stroke. Cochrane Database Syst Rev. 2008;(1):CD000480. [pmid: 18253980].
Berman M, Erman A, Ben-Gal T, et al. Coenzyme Q10 in patients with end-stage heart failure awaiting cardiac transplantation: a randomized, placebo-controlled study. Clin Cardiol. May. 2004;27(5):295-9. [pmid: 15188947].
Berry NM, Rickards CA, Newman DG. The effect of caffeine on the cardiovascular responses to head-up tilt. Aviat Space Environ Med. Jul. 2003;74(7):725-30. [pmid: 12862326].
Berthold HK, Sudhop T, von BK. Effect of a garlic oil preparation on serum lipoproteins and cholesterol metabolism: a randomized controlled trial. JAMA. 1998;279(23):1900-2. [pmid: 9634262].
Bjelakovic G, Nikolova D, Gluud LL, et al. Mortality in randomized trials of antioxidant supplements for primary and secondary prevention: systematic review and meta-analysis. JAMA. Feb. 28. 2007;297(8):842-57. [pmid: 17327526].
Bjelakovic G, Nikolova D, Gluud LL, et al. Antioxidant supplements for prevention of mortality in healthy participants and patients with various diseases [Cochrane review]. Cochrane Database of Systematic Reviews 2008. Chichester (UK). John Wiley & Sons, Ltd. 2008;(2):2.
Bleys J, Miller ER III, Pastor-Barriuso R, et al. Vitamin-mineral supplementation and the progression of atherosclerosis: a meta-analysis of randomized controlled trials. Am J Clin Nutr. Oct. 2006;84(4):880-7. [pmid: 17023716].
Bloom OJ, McDiarmid T, Scoville C. Clinical inquiries. Do antioxidants (vitamins C, E) improve outcomes in patients with coronary artery disease?. J Fam Pract. Nov. 2002;51(11):978. [pmid: 12485557].
Bloomer RJ, Tschume LC, Smith WA. Glycine propionyl-L-carnitine modulates lipid peroxidation and nitric oxide in human subjects. Int J Vitam Nutr Res. May. 2009;79(3):131-41. [pmid: 20209464].
Blume J, Kieser M, Hölscher U. Placebo-controlled double-blind study of the effectiveness of Ginkgo biloba special extract EGb 761 in trained patients with intermittent claudication. [German]. Vasa. 1996;25(3):265-74. [pmid: 8967154].
Bogsrud MP, Ose L, Langslet G, et al. HypoCol (red yeast rice) lowers plasma cholesterol - a randomized placebo controlled study. Scand Cardiovasc J. Aug. 2010;44(4):197-200. [pmid: 20636227].
Bogsrud MP, Ose L, Langslet G, et al. HypoCol (red yeast rice) lowers plasma cholesterol - a randomized placebo controlled study. Scand Cardiovasc J. Aug. 2010;44(4):197-200. [pmid: 20636227].
Booth SL, Golly I, Sacheck JM, et al. Effect of vitamin E supplementation on vitamin K status in adults with normal coagulation status. Am J Clin Nutr. Jul. 2004;80(1):143-8. [pmid: 15213041].
Bordia A, Chuttani SK. Effect of gum guggulu on fibrinolysis and platelet adhesiveness in coronary heart disease. Indian J Med Res. Dec. 1979;70:992-6. [pmid: 396237].
Borovnicar A, Keber I, Stavljenic RA, et al. Improvement of early functional atherosclerotic changes in males with hypercholesterolemia after vitamin E supplementation. Pflugers Arch. 2000;440(5 Suppl):R126-128. [pmid: 11005639].
Borthwick L. The effects of an omega-3 ethyl ester concentrate on blood lipid concentrations in patients with hyperlipidaemia. Clin Drug Invest. 1998;15(5):397-404. [pmid: 18370495].
Boshtam M, Rafiei M, Sadeghi K, et al. Vitamin E can reduce blood pressure in mild hypertensives. Int J Vitam Nutr Res. Oct. 2002;72(5):309-14. [pmid: 12463106].
Braden GA, Knapp HR, FitzGerald GA. Suppression of eicosanoid biosynthesis during coronary angioplasty by fish oil and aspirin. Circ Cardiovasc Qual Outcomes. Aug. 1991;84(2):679-85. [pmid: 1860212].
Brevetti G, Attisano T, Perna S, et al. Effect of L-carnitine on the reactive hyperemia in patients affected by peripheral vascular disease: a double-blind, crossover study. Angiology. Oct. 1989;40(10):857-62. [pmid: 2679240].
Brinkley TE, Lovato JF, Arnold AM, et al. Effect of Ginkgo biloba on blood pressure and incidence of hypertension in elderly men and women. Am J Hypertens. 2010;23(5):528-33. [pmid: 20168306].
Brinkley TE, Lovato JF, Arnold AM, et al. Effect of Ginkgo biloba on blood pressure and incidence of hypertension in elderly men and women. American Journal o 1f40 f Hypertension. May. 2010;23(5):528-33. [pmid: 20168306].
Brodsky MA, Orlov MV, Capparelli EV, et al. Magnesium therapy in new-onset atrial fibrillation. [Erratum appears in Am J Cardiol 1994 Sep 15;74(6):639]. Am J Cardiol. Jun. 15. 1994;73(16):1227-9. [pmid: 8203347].
Brousseau ME, Schaefer EJ. Diet and coronary heart disease: clinical trials. [Review] [48 refs]. Curr Atheroscler Rep. Nov. 2000;2(6):487-93. [pmid: 11122783].
Brouwer IA, Zock PL, Wever EF, et al. Rationale and design of a randomised controlled clinical trial on supplemental intake of n-3 fatty acids and incidence of cardiac arrhythmia: SOFA. Eur J Clin Nutr. Oct. 2003;57(10):1323-30. [pmid: 14506496].
Brox JH, Killie JE, Osterud B, et al. Effects of cod liver oil on platelets and coagulation in familial hypercholesterolemia (type IIa). Acta Med Scand. 1983;213(2):137-44. [pmid: 6340424].
Bucher HC, Cook RJ, Guyatt GH, et al. Effects of dietary calcium supplementation on blood pressure. A meta-analysis of randomized controlled trials. JAMA. Apr. 3. 1996;275(13):1016-22. [pmid: 8596234].
Bucher HC, Hengstler P, Schindler C, et al. N-3 polyunsaturated fatty acids in coronary heart disease: a meta-analysis of randomized controlled trials (DARE structured abstract). Am J Med. 2002;112:298-304. [pmid: 11893369].
Buettner C, Yeh GY, Phillips RS, et al. Systematic review of the effects of ginseng on cardiovascular risk factors (DARE structured abstract). Ann Pharmacother. 2006;40:83-95. [pmid: 16332943].
Buettner C, Yeh GY, Phillips RS, et al. Systematic review of the effects of ginseng on cardiovascular risk factors. [Review] [63 refs]. Ann Pharmacother. Jan. 2006;40(1):83-95. [pmid: 16332943].
Burke BE, Neuenschwander R, Olson RD. Randomized, double-blind, placebo-controlled trial of coenzyme Q10 in isolated systolic hypertension. South Med J. Nov. 2001;94(11):1112-7. [pmid: 11780680].
Bursell SE, Clermont AC, Aiello LP, et al. High-dose vitamin E supplementation normalizes retinal blood flow and creatinine clearance in patients with type 1 diabetes. Diabetes Care. Aug. 1999;22(8):1245-51. [pmid: 10480765].
Byington R, Goldstein S. Association of digitalis therapy with mortality in survivors of acute myocardial infarction: observations in the Beta-Blocker Heart Attack Trial. J Am Coll Cardiol. 1985;6(5):976-82. [pmid: 4045047].
Canner PL, Furberg CD, Terrin ML, et al. Benefits of niacin by glycemic status in patients with healed myocardial infarction (from the Coronary Drug Project). Am J Cardiol. Jan. 15. 2005;95(2):254-7. [pmid: 15642562].
Canner PL, Furberg CD, McGovern ME. Benefits of niacin in patients with versus without the metabolic syndrome and healed myocardial infarction (from the Coronary Drug Project). Am J Cardiol. Feb. 15. 2006;97(4):477-9. [pmid: 16461040].
Cappuccio FP, Markandu ND, Beynon GW, et al. Lack of effect of oral magnesium on high blood pressure: a double blind study. Br Med J (Clin Res Ed). Jul. 27. 1985;291(6490):235-8. [pmid: 3926135].
Cappuccio FP, Siani A, Strazzullo P. Oral calcium supplementation and blood pressure: an overview of randomized controlled trials. J Hypertens. Dec. 1989;7(12):941-6. [pmid: 2697729].
Cappuccio FP, MacGregor GA. Does potassium supplementation lower blood pressure? A meta-analysis of published trials. J Hypertens. May. 1991;9(5):465-73. [pmid: 1649867].
Cappuccio FP, Elliott P, Allender PS, et al. Epidemiologic association between dietary calcium intake and blood pressure: a meta-analysis of published data. Am J Epidemiol. Nov. 1. 1995;142(9):935-45. [pmid: 7572974].
Carpenter KL, Kirkpatrick PJ, Weissberg PL, et al. Oral alpha-tocopherol supplementation inhibits lipid oxidation in established human atherosclerotic lesions. Free Radic Res. Nov. 2003;37(11):1235-44. [pmid: 14703736].
Caughey GE, James MJ, Proudman SM, et al. Fish oil supplementation increases the cyclooxygenase inhibitory activity of paracetamol in rheumatoid arthritis patients. Complementary Therapies in Medicine. 2010;18(3-4):171-174. Date of Publication: June 2010 2010;(3–4):171–4. [pmid: 20688263].
Chan DC, Watts GF, Mori TA, et al. Randomized controlled trial of the effect of n-3 fatty acid supplementation on the metabolism of apolipoprotein B-100 and chylomicron remnants in men with visceral obesity. Am J Clin Nutr. Feb. 2003;77(2):300-7. [pmid: 12540386].
Chan YH, Lau KK, Yiu KH, et al. Reduction of C-reactive protein with isoflavone supplement reverses endothelial dysfunction in patients with ischaemic stroke. Eur Heart J. Nov. 2008;29(22):2800-7. [pmid: 18812325].
Chandra RK. Influence of multinutrient supplement on immune responses and infection-related illness in 50–65 year old individuals. Nutrition Research. 2002;22(1-2):5-11. Date of Publication 2002 2002;(1–2):5–11.
Chello M, Mastroroberto P, Romano R, et al. Protection by coenzyme Q10 from myocardial reperfusion injury during coronary artery bypass grafting. Ann Thorac Surg. Nov. 1994;58(5):1427-32. [pmid: 7979670].
Chen H, Karne RJ, Hall G, et al. High-dose oral vitamin C partially replenishes vitamin C levels in patients with Type 2 diabetes and low vitamin C levels but does not improve endothelial dysfunction or insulin resistance. Am J Physiol Heart Circ Physiol. Jan. 2006;290(1):H137-145. [pmid: 16126809].
Chen X. Cardiovascular protection by ginsenosides and their nitric oxide releasing action. [Review] [19 refs]. Clinical & Experimental Pharmacolog 1f40 y & Physiology. Aug. 1996;23(8):728-32. [pmid: 8886498].
Chen X, Zhou M, Li Q, et al. Sanchi for acute ischaemic stroke. Cochrane Database Syst Rev. 2008;(4):CD006305. [pmid: 18843711].
Chesney CM, Elam MB, Herd JA, et al. Effect of niacin, warfarin, and antioxidant therapy on coagulation parameters in patients with peripheral arterial disease in the Arterial Disease Multiple Intervention Trial (ADMIT). Am Heart J. Oct. 2000;140(4):631-6. [pmid: 11011338].
Chiarelli F, Santilli F, Sabatino G, et al. Effects of vitamin E supplementation on intracellular antioxidant enzyme production in adolescents with type 1 diabetes and early microangiopathy. Pediatr Res. Nov. 2004;56(5):720-5. [pmid: 15347773].
Chin JP, Dart AM. HBPRCA Astra Award. Therapeutic restoration of endothelial function in hypercholesterolaemic subjects: effect of fish oils. Clin Exp Pharmacol Physiol. Oct. 1994;21(10):749-55. [pmid: 7867225].
Christen WG, Manson JE, Glynn RJ, et al. Beta carotene supplementation and age-related maculopathy in a randomized trial of US physicians. Arch Ophthalmol. Mar. 2007;125(3):333-9. [pmid: 17353403].
Christensen JH, Gustenhoff P, Korup E, et al. Effect of fish oil on heart rate variability in survivors of myocardial infarction: a double blind randomised controlled trial. BMJ. Mar. 16. 1996;312(7032):677-8. [pmid: 8597736].
Chrubasik S, Droste C, Dragano N, et al. Effectiveness and tolerability of the herbal mixture Asparagus P on blood pressure in treatment-requiring antihypertensives. Phytomedicine. Nov. 2006;13(9–10):740-2. [pmid: 16488123].
Chung KF, Dent G, McCusker M, et al. Effect of a ginkgolide mixture (BN 52063) in antagonising skin and platelet responses to platelet activating factor in man. La 1f40 ncet. 1987;1(8527):248-51.
Clark W, Jobanputra P, Barton P, et al. The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis. Health Technol Assess. Jan. 10. 2001;8(18):iii-x. 1.
Cleghorn CL, Skeaff CM, Mann J, et al. Plant sterol-enriched spread enhances the cholesterol-lowering potential of a fat-reduced diet. European Journal of Clinical Nutrition. 2003;57(1):170-176. Date of Publication: 01 Jan 2003 2003;(1):170–6. [pmid: 12548313].
Cleland LG, Caughey GE, James MJ, et al. Reduction of cardiovascular risk factors with longterm fish oil treatment in early rheumatoid arthritis. J Rheumatol. 2006;33(10):1973-9. [pmid: 16881100].
Colonna P, Iliceto S. Myocardial infarction and left ventricular remodeling: results of the CEDIM trial. Carnitine Ecocardiografia Digitalizzata Infarto Miocardico. [Review] [28 refs]. Am Heart J. Feb. 2000;139(2 Pt 3):S124-130. [pmid: 10650326].
Constantinescu R, McDermott MP, DiCenzo R, et al. A randomized study of the bioavailability of different formulations of coenzyme Q_10_ (ubiquinone). Journal of Clinical Pharmacology. 2007;47(12):1580-1586. Date of Publication: Dec 2007 2007;(12):1580–6. [pmid: 17925590].
Contacos C, Barter PJ, Sullivan DR. Effect of pravastatin and omega-3 fatty acids on plasma lipids and lipoproteins in patients with combined hyperlipidemia. Arterioscler Thromb. Dec. 1993;13(12):1755-62. [pmid: 8241095].
Costeff H, Apter N, Elpeleg ON, et al. Ineffectiveness of oral coenzyme Q10 supplementation in 3-methylglutaconic aciduria, type 3. Brain and Development. 1998;20(1):33-35. Date of Publication: Jan 1998 1998;(1):33–5. [pmid: 9533558].
Crawford V, Scheckenbach R, Preuss HG. Effects of niacin-bound chromium supplementation on body composition in overweight African-American women. Diabetes Obes Metab. Nov. 1999;1(6):331-7. [pmid: 11225649].
Croset M, Véricel E, Rigaud M, et al. Functions and tocopherol content of blood platelets from elderly people after low intake of purified eicosapentaenoic acid. Thromb Res. Jan. 1. 1990;57(1):1-12. [pmid: 2105538].
Crowther MA, Ageno W, Schnurr T, et al. Oral vitamin K produces a normal INR within 24 hours of its administration in most patients discontinuing warfarin. Haematologica. Jan. 2005;90(1):137-9. [pmid: 15642685].
Dabbagh OC, Aldawood AS, Arabi YM, et al. Magnesium supplementation and the potential association with mortality rates among critically ill non-cardiac patients. Saudi Med J. Jun. 2006;27(6):821-5. [pmid: 16758043].
Dagenais GR, Marchioli R, Yusuf S, et al. Beta-carotene, vitamin C, and vitamin E and cardiovascular diseases. [Review] [44 refs]. Curr Cardiol Rep. Jul. 2000;2(4):293-9. [pmid: 10953262].
Damian MS, Ellenberg D, Gildemeister R, et al. Coenzyme Q10 combined with mild hypothermia after cardiac arrest: a preliminary study. Circ Cardiovasc Qual Outcomes. Nov. 9. 2004;110(19):3011-6. [pmid: 15520321].
Daniele C, Coon JT, Pittler MH, et al. Vitex agnus castus: A systematic review of adverse events. Drug Saf. 2005;28(4):319-32. [pmid: 15783241].
Dasgupta A, Bernard DW. Herbal remedies: effects on clinical laboratory tests. [Review] [98 refs]. Arch Pathol Lab Med. Apr. 2006;130(4):521-8. [pmid: 16594744].
Dawson-Hughes B, Harris SS, Krall EA, et al. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. Sep. 4. 1997;337(10):670-6. [pmid: 9278463].
de Meirelles LR, Mendes-Ribeiro AC, Santoro MM, et al. Inhibitory effects of endogenous L-arginine analogues on nitric oxide synthesis in platelets: role in platelet hyperaggregability in hypertension. Clin Exp Pharmacol Physiol. Dec. 2007;34(12):1267-71. [pmid: 17973865].
de GG. Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. [Erratum appears in Lancet 2001 Apr 7;357(9262):1134]. La 1f40 ncet. Jan. 13. 2001;357(9250):89-95. [pmid: 11197445].
de LM, Boissonnat P, Salen P, et al. The beneficial effect of dietary antioxidant supplementation on platelet aggregation and cyclosporine treatment in heart transplant recipients. Transplantation. Jul. 27. 1994;58(2):193-5. [pmid: 8042237].
Dembinska-Kiec A, Zmuda A, Bieron K, et al. Plasma antioxidant potency and serum copper levels in atherosclerosis. Pol J Pharmacol Pharm. Mar. 1985;37(2):123-32. [pmid: 3900961].
Demeyere R, Lormans P, Van AH, et al. Cardioprotective effects of carnitine in extensive aorto-coronary bypass grafting. J Cardiothorac Anesth. Oct. 1989;3(5 Suppl 1):5. [pmid: 2520987].
Demeyere R, Lormans P, Weidler B, et al. Cardioprotective effects of carnitine in extensive aortocoronary bypass grafting: a double-blind, randomized, placebo-controlled clinical trial. Anesth Analg. Nov. 1990;71(5):520-8. [pmid: 2221413].
Dentali F, Ageno W, Crowther M. Treatment of coumarin-associated coagulopathy: a systematic review and proposed treatment algorithms. [Review] [60 refs]. J Thromb Haemost. Sep. 2006;4(9):1853-63. [pmid: 16961594].
Desideri G, Marinucci MC, Tomassoni G, et al. Vitamin E supplementation reduces plasma vascular cell adhesion molecule-1 and von Willebrand factor levels and increases nitric oxide concentrations in hypercholesterolemic patients. J Clin Endocrinol Metab. Jun. 2002;87(6):2940-5. [pmid: 12050277].
Devaraj S, Chan AV Jr, Jialal I. alpha-Tocopherol supplementation decreases plasminogen activator inhibitor-1 and P-selectin levels in type 2 diabetic patients. Diabetes Care. Mar. 2002;25(3):524-9. [pmid: 11874941].
Dhar R, Stout CW, Link MS, et al. Cardiovascular toxicities of performance-enhancing substances in sports. [Review] [101 refs][Erratum appears in Mayo Clin Proc.2006 Jan;81(1):133]. Mayo Clin Proc. Oct. 2005;80(10):1307-15. [pmid: 16212144].
Dhawan V, Jain S. Garlic supplementation prevents oxidative DNA damage in essential hypertension. Mol Cell Biochem. Jul. 2005;275(1–2):85-94. [pmid: 16335787].
Diamond BJ, Shiflett SC, Feiwel N, et al. Ginkgo biloba extract: mechanisms and clinical indications. [Review] [120 refs]. Arch Phys Med Rehabil. May. 2000;81(5):668-78. [pmid: 10807109].
Dickinson HO, Nicolson D, Campbell F, et al. Magnesium supplementation for the management of primary hypertension in adults [Cochrane review]. Cochrane Database of Systematic Reviews 2006. Chichester (UK). John Wiley & Sons, Ltd. 2006;(3):3.
Dmoszynska-Giannopoulou A, Janicka L, Sokolowska B, et al. The effect of sulphinpyrazone and alpha-tocopherol on platelet activation and function in haemodialysed patients. Int Urol Nephrol. 1990;22(6):561-6. [pmid: 2093696].
Dokholyan RS, Albert CM, Appel LJ, et al. A trial of omega-3 fatty acids for prevention of hypertension. Am J Cardiol. Apr. 15. 2004;93(8):1041-3. [pmid: 15081453].
Donadio JV Jr, Bergstralh EJ, Offord KP, et al. A controlled trial of fish oil in IgA nephropathy. Mayo Nephrology Collaborative Group. N Engl J Med. Nov. 3. 1994;331(18):1194-9. [pmid: 7935657].
Donnelly SM. Effect of n-3 fatty acids from fish oil on hemostasis, blood pressure, and lipid profile of dialysis patients. J Am Soc Nephrol. 1992;2(11):1634-9. [pmid: 1610984].
Driss F, Vericel E, Lagarde M, et al. Inhibition of platelet aggregation and thromboxane synthesis after intake of small amount of icosapentaenoic acid. Thromb Res. Dec. 1. 1984;36(5):389-96. [pmid: 6098051].
Du Plooy WJ, Venter CP, Muntingh GM, et al. The cumulative dose response effect of eicosapentaenoic and docosahexaenoic acid on blood pressure, plasma lipid profile and diet pattern in mild to moderate essential hypertensive black patients. Prostaglandins Leukot Essent Fatty Acids. Aug. 1992;46(4):315-21. [pmid: 1409770].
Dubé L, Granry JC. The therapeutic use of magnesium in anesthesiology, intensive care and emergency medicine: a review. [Review] [115 refs]. Can J Anaesth. Aug. 2003;50(7):732-46. [pmid: 12944451].
Duche JC, Barre J, Guinot P, et al. Effect of Ginkgo biloba extract on microsomal enzyme induction. Int J Clin Pharmacol Res. 1989;9(3):165-8. [pmid: 2744909].
Duffy EM, Meenagh GK, McMillan SA, et al. The clinical effect of dietary supplementation with omega-3 fish oils and/or copper in systemic lupus erythematosus. J Rheumatol. Aug. 2004;31(8):1551-6. [pmid: 15290734].
Duong TM, Plowman BK, Morreale AP, et al. Retrospective and prospective analyses of the treatment of overanticoagulated patients. Pharmacotherapy. Nov. 1998;18(6):1264-70. [pmid: 9855325].
Dyckner T, Wester PO. Effect of magnesium on blood pressure. Br Med J (Clin Res Ed). Jun. 11. 1983;286(6381):1847-9. [pmid: 6407598].
Dyckner T, Wester PO, Widman L. Effects of peroral magnesium on plasma and skeletal muscle electrolytes in patients on long-term diuretic therapy. Int J Cardiol. Apr. 1988;19(1):81-7. [pmid: 3372076].
Ebrahimi M, Ghayour-Mobarhan M, Rezaiean S, et al. Omega-3 fatty acid supplements improve the cardiovascular risk profile of subjects with metabolic syndrome, including markers of inflammation and auto-immunity. Acta Cardiol. Jun. 2009;64(3):321-7. [pmid: 19593941].
Eckmann F. Cerebral insufficiency--treatment with Ginkgo-biloba extract. Time of onset of effect in a double-blind study with 60 inpatients. [German]. Fortschr Med Orig. Oct. 10. 1990;108(29):557-60. [pmid: 2242846].
Eidelman RS, Hollar D, Hebert PR, et al. Randomized trials of vitamin E in the treatment and prevention of cardiovascular disease. Arch Intern Med. Jul. 26. 2004;164(14):1552-6. [pmid: 15277288].
Engelen W, Keenoy B, Vertommen J, et al. Effects of micronized fenofibrate and vitamin E on in vitro oxidation of lipoproteins in patients with type 1 diabetes mellitus. Diabetes Metab. Apr. 2005;31(2):197-204. [pmid: 15959426].
Eritsland J, Arnesen H, Seljeflot I, et al. Long-term metabolic effects of n-3 polyunsaturated fatty acids in patients with coronary artery disease. American Journal of Clinical Nutrition. 1995;61(4):831-836. Date of Publication: Apr 1995 1995;(4):831–6. [pmid: 7702027].
Ernst E, Rand JI, Barnes J, et al. Adverse effects profile of the herbal antidepressant St. John's wort (Hypericum perforatum L.). Eur J Clin Pharmacol. 1998;54(8):589-94. [pmid: 9860144].
Ernst E. Adverse effects of unconventional therapies in the elderly: A systematic review of the recent literature. J Am Aging Assoc. 2002;25(1):11-20.
Eussen SJ, Ueland PM, Clarke R, et al. The association of betaine, homocysteine and related metabolites with cognitive function in Dutch elderly people. Br J Nutr. Nov. 2007;98(5):960-8. [pmid: 17537289].
Fabbrini E, Mohammed BS, Korenblat KM, et al. Effect of fenofibrate and niacin on intrahepatic triglyceride content, very low-density lipoprotein kinetics, and insulin action in obese subjects with nonalcoholic fatty liver disease. J Clin Endocrinol Metab. Jun. 2010;95(6):2727-35. [pmid: 20371660].
Fan XF, Deng YQ, Ye L, et al. Effect of Xuezhikang Capsule on serum tumor necrosis factor-alpha and interleukin-6 in patients with nonalcoholic fatty liver disease and hyperlipidemia. Chin J Integr Med. Apr. 2010;16(2):119-23. [pmid: 20473736].
Fasching P, Ratheiser K, Waldhäusl W, et al. Fish oil as lipostatic factor. [German]. Vasa Suppl. 1990;30:62-3. [pmid: 2075591].
Faust TW, Redfern JS, Podolsky I, et al. Effects of aspirin on gastric mucosal prostaglandin E2 and F2 alpha content and on gastric mucosal injury in humans receiving fish oil or olive oil. Gastroenterology. Mar. 1990;98(3):586-91. [pmid: 2298365].
Feldstedt M, Boesgaard S, Bouchelouche P, et al. Magnesium substitution in acute ischaemic heart syndromes. Eur Heart J. Nov. 1991;12(11):1215-8. [pmid: 1782952].
Feltner DE, Hertzman M. Progress in the treatment of tardive dyskinesia: theory and practice. [Review] [77 refs]. Hosp Community Psychiatry. Jan. 1993;44(1):25-34. [pmid: 8094705].
Ferrara LA, Iannuzzi R, Castaldo A, et al. Long-term magnesium supplementation in essential h 1f40 ypertension. Cardiology. 1992;81(1):25-33. [pmid: 1477853].
Fetrow CW, Avila JR. Efficacy of the dietary supplement S-adenosyl-L-methionine. Ann Pharmacother. 2001;35(11):1414-25. [pmid: 11724095].
Filion KB, El KF, Bielinski M, et al. Omega-3 fatty acids in high-risk cardiovascular patients: a meta-analysis of randomized controlled trials. [Review]. BMC Cardiovasc Disord. 2010;10:24. [pmid: 20525225].
Fisman EZ, Tenenbaum A, Shapira I, et al. The nitric oxide pathway: is L-arginine a gate to the new millennium medicine? A meta-analysis of L-arginine effects. J. 1999;30(3–4):131-48. [pmid: 17312667].
Fleischhauer FJ, Yan WD, Fischell TA. Fish oil improves endothelium-dependent coronary vasodilation in heart transplant recipients. J Am Coll Cardiol. Mar. 15. 1993;21(4):982-9. [pmid: 8450169].
Flores-Mateo G, Navas-Acien A, Pastor-Barriuso R, et al. Selenium and coronary heart disease: a meta-analysis. Am J Clin Nutr. Oct. 2006;84(4):762-73. [pmid: 17023702].
Fuchs J, Beigel Y, Green P, et al. Big platelets in hyperlipidemic patients. J Clin Pharmacol. Jul. 1992;32(7):639-42. [pmid: 1640003].
Fumeron F, Brigant L, Ollivier V, et al. n-3 polyunsaturated fatty acids raise low-density lipoproteins, high-density lipoprotein 2, and plasminogen-activator inhibitor in healthy young men. Am J Clin Nutr. Jul. 1991;54(1):118-22. [pmid: 2058572].
Gardner CD, Lawson LD, Block E, et al. Effect of raw garlic vs commercial garlic supplements on plasma lipid concentrations in adults with moderate hypercholesterolemia: a randomized clinical trial. Arch Intern Med. Feb. 26. 2007;167(4):346-53. [pmid: 17325296].
Garland ML, Hagmeyer KO. The role of zinc lozenges in treatment of the common cold (DARE structured abstract). Ann Pharmacother. 1998;32:63-9. [pmid: 9475824].
Gazis A, White DJ, Page SR, et al. Effect of oral vitamin E (alpha-tocopherol) supplementation on vascular endothelial function in Type 2 diabetes mellitus. Diabet Med. Apr. 1999;16(4):304-11. [pmid: 10220204].
Geelen A, Brouwer IA, Schouten EG, et al. Effects of n-3 fatty acids from fish on premature ventricular complexes and heart rate in humans. Am J Clin Nutr. Feb. 2005;81(2):416-20. [pmid: 15699229].
Gheith O, Sheashaa H, Abdelsalam M, et al. Efficacy and safety of Monascus purpureus Went rice in subjects with secondary hyperlipidemia. Clin Exp Nephrol. Jun. 2008;12(3):189-94. [pmid: 18363032].
Gheith O, Sheashaa H, Sobh M, et al. Monascus purpureus Went rice in nephrotic hyperlipidemia. Indian J. Apr. 2008;18(2):58-63. [pmid: 20142904].
Glover EI, Martin J, Maher A, et al. A randomized trial of coenzyme Q10 in mitochondrial disorders. Muscle Nerve. Nov. 2010;42(5):739-48. [pmid: 20886510].
Green D, O'Driscoll G, Blanksby B, et al. Lack of effect of vitamin E administration on basal nitric oxide function in male smokers and non-smokers. Clin Sci (Colch). Oct. 1995;89(4):343-8. [pmid: 7493433].
Greenblatt DJ, von Moltke LL, Luo Y, et al. Ginkgo biloba does not alter clearance of flurbiprofen, a cytochrome P450-2C9 substrate. J Clin Pharmacol. Feb. 2006;46(2):214-21. [pmid: 16432273].
Greenway FL, Raum WJ, DeLany JP. The effect of an herbal dietary supplement containing ephedrine and caffeine on oxygen 1f40 consumption in humans. J Altern Complement Med. Dec. 2000;6(6):553-5. [pmid: 11152061].
Grossman E, Messerli FH, Goldbourt U. Antihypertensive therapy and the risk of malignancies. [Review] [97 refs]. Eur Heart J. Aug. 2001;22(15):1343-52. [pmid: 11465967].
Grundt H, Nilsen DW, Mansoor MA, et al. Reduction in homocysteine by n-3 polyunsaturated fatty acids after 1 year in a randomised double-blind study following an acute myocardial infarction: no effect on endothelial adhesion properties. Pathophysiol Haemost Thromb. Mar. 2003;33(2):88-95. [pmid: 14624050].
Guallar E, Hennekens CH, Sacks FM, et al. A prospective study of plasma fish oil levels and incidence of myocardial infarction in U.S. male physicians. J Am Coll Cardiol. Feb. 1995;25(2):387-94. [pmid: 7829792].
Rodríguez-Morán M M, Guerrero-Romero F. Oral magnesium supplementation improves insulin sensitivity and metabolic control in type 2 diabetic subjects: a randomized double-blind controlled trial. Diabetes Care. Apr. 2003;26(4):1147-52. [pmid: 12663588].
Gurley BJ, Gardner SF, Hubbard MA, et al. Cytochrome P450 phenotypic ratios for predicting herb-drug interactions in humans. Clinical Pharmacology and Therapeutics. 2002;72(3):276-287. Date of Publication: Sep 2002 2002;(3):276–87. [pmid: 12235448].
Gurley BJ, Gardner SF, Hubbard MA, et al. Clinical assessment of effects of botanical supplementation on cytochrome P450 phenotypes in the elderly: St John's wort, garlic oil, Panax ginseng and Ginkgo biloba. Drugs & Aging. 2005;22(6):525-39. [pmid: 15974642].
Gurley BJ, Barone GW, Williams DK, et al. Effect of milk thistle (Silybum marianum) and black cohosh (Cimicifuga racemosa) supplementation on digoxin pharmacokinetics in humans. Drug Metab Dispos. Jan. 2006;34(1):69-74. [pmid: 16221754].
Hadjistavri LS, Sarafidis PA, Georgianos PI, et al. Beneficial effects of oral magnesium supplementation on insulin sensitivity and serum lipid profile. Med Sci Monit. Jun. 2010;16(6):I13-18.
Haeger K. Long-time treatment of intermittent claudication with vitamin E. Am J Clin Nutr. Oct. 1974;27(10):1179-81. [pmid: 4138090].
Haglund O. Effects of fish oil supplemented with pyridoxine and folic acid on homocysteine, atherogenic index, fibrinogen and plasminogen activator inhibitor-1 in man. Nutr Res. 1993;13:1351-65.
Hajjar I, Kotchen T. Regional variations of blood pressure in the United States are associated with regional variations in dietary intakes: the NHANES-III data. J Nutr. Jan. 2003;133(1):211-4. [pmid: 12514292].
Hambsch K. Degrees of severity of drug interactions. [German]. Z Arztl Fortbild (Jena). Jun. 1. 1981;75(11–12):545. [pmid: 7303750].
Hammerl H, Kränzl C, Nebosis G, et al. Effect of a combination of vasoactive substances on metabolism and the rheoencephalogram. [German]. Wien Klin Wochenschr. Sep. 15. 1973;123(37):533-8. [pmid: 4148002].
Harland JI, Haffner TA. Systematic review, meta-analysis and regression of randomised controlled trials reporting an association between an intake of circa 25 g soya protein per day and blood cholesterol. [Review] [62 refs]. Atherosclerosis. Sep. 2008;200(1):13-27. [pmid: 18534601].
Harper CR, Jacobson TA. Usefulness of omega-3 fatty acids and the prevention of coronary heart disease. American Journal of Cardiology. 2005;96(11):1521-1529. Date of Publication: 01 Dec 2005 2005;(11):1521–9. [pmid: 16310434].
Harris WS, Rambj&#x00F8, r GS, et al. n-3 fatty acids and urinary excretion of nitric oxide metabolites in humans. Am J Clin Nutr. Feb. 1997;65(2):459-64. [pmid: 9022531].
Harris WS, Dujovne CA, Windsor SL, et al. Inhibiting cholesterol absorption with CP-88,818 (beta-tigogenin cellobioside; tiqueside): studies in normal and hyperlipidemic subjects. J Cardiovasc Pharmacol. Jul. 1997;30(1):55-60. [pmid: 9268221].
Hartweg J, Farmer AJ, Holman RR, et al. Meta-analysis of the effects of n-3 polyunsaturated fatty acids on haematological and thrombogenic factors in type 2 diabetes. Diabe 1f40 tologia. Feb. 2007;50(2):250-8. [pmid: 17119918].
Hatzigeorgiou C, Taylor AJ, Feuerstein IM, et al. Antioxidant vitamin intake and subclinical coronary atherosclerosis. Prev Cardiol. 2006;9(2):75-81. [pmid: 16603825].
Hatzistavri LS, Sarafidis PA, Georgianos PI, et al. Oral magnesium supplementation reduces ambulatory blood pressure in patients with mild hypertension. Am J Hypertens. Oct. 2009;22(10):1070-5. [pmid: 19617879].
Hayden KM, Welsh-Bohmer KA, Wengreen HJ, et al. Risk of mortality with vitamin E supplements: the Cache County study. Am J Med. Feb. 2007;120(2):180-4. [pmid: 17275460].
Heber D, Yip I, Ashley JM, et al. Cholesterol-lowering effects of a proprietary Chinese red-yeast-rice dietary supplement. American Journal of Clinical Nutrition. 1999;69(2):231-236. Date of Publication: Feb 1999 1999;(2):231–6. [pmid: 9989685].
Heitzer T, Herttuala S, Wild E, et al. Effect of vitamin E on endothelial vasodilator function in patients with hypercholesterolemia, chronic smoking or both. J Am Coll Cardiol. Feb. 1999;33(2):499-505. [pmid: 9973031].
Herrmann W, Biermann J, Kostner GM. Comparison of effects of N-3 to N-6 fatty acids on serum level of lipoprotein(a) in patients with coronary artery disease. Am J Cardiol. Sep. 1. 1995;76(7):459-62. [pmid: 7653444].
Hirai A, Terano T, Tamura Y, et al. Eicosapentaenoic acid and adult diseases in Japan: epidemiological and clinical aspects. J Intern Med. Supplement. 731. 1989:69-75. [pmid: 2784161].
Ho MJ, Bellusci A, Wright JM. Blood pressure lowering efficacy of coenzyme Q10 for primary hypertension. [Review] [25 refs]. Cochrane Database Syst Rev. 2009;(4):CD007435. [pmid: 19821418].
Hodges RE. Vitamin E and coronary heart disease. [Review] [61 refs]. J Am Diet Assoc. Jun. 1973;62(6):638-42. [pmid: 4576935].
Hodgson JM, Watts GF, Playford DA, et al. Coenzyme Q10 improves blood pressure and glycaemic control: a controlled trial in subjects with type 2 diabetes. Eur J Clin Nutr. Nov. 2002;56(11):1137-42. [pmid: 12428181].
Hodis HN, Mack WJ, LaBree L, et al. Serial coronary angiographic evidence that antioxidant vitamin intake reduces progression of coronary artery atherosclerosis. J Am Med Assoc. Jun. 21. 1995;273(23):1849-54. [pmid: 7776501].
Hoffman RM, Garewal HS. Alpha-tocopherol supplementation for men with existing coronary artery disease: a feasibility study. [Erratum appears in Prev Med 2000 Jan;30(1):80]. Prev Med. Aug. 1999;29(2):112-8. [pmid: 10446037].
Hogg RJ, Lee J, Nardelli N, et al. Clinical trial to evaluate omega-3 fatty acids and alternate day prednisone in patients with IgA nephropathy: report from the Southwest Pediatric Nephrology Study Group. Clin J Am Soc Nephrol. May. 2006;1(3):467-74. [pmid: 17699247].
Holguin F, Tellez-Rojo MM, Lazo M, et al. Cardiac autonomic changes associated with fish oil vs soy oil supplementation in the elderly. Chest. 2005;127(4):1102-1107. Date of Publication: Apr 2005 2005;(4):1102–7. [pmid: 15821181].
Holm T, Andreassen AK, Aukrust P, et al. Omega-3 fatty acids improve blood pressure control and preserve renal function in hypertensive heart transplant recipients. Eur Heart J. Mar. 2001;22(5):428-36. [pmid: 11207085].
Holman RR, Steemson J, Darling P, et al. No glycemic benefit from guar administration in NIDDM. Diabetes Care. 1987;10(1):68-71. [pmid: 3032537].
Holubarsch CJ, Colucci WS, Meinertz T, et al. The efficacy and safety of Crataegus extract WS 1442 in patients with heart failure: the SPICE trial. Eur J Heart Fail. Dec. 2008;10(12):1255-63. [pmid: 19019730].
Holzgartner H, Maier E, Vierling W. High-dosage oral magnesium therapy in arrhythmias. Results of an observational study in 1.160 patients with arrhythmia. [German]. Fortschr Med Orig. Sep. 30. 1990;108(28):539-42. [pmid: 2242840].
Hooper L, Griffiths E, Abrahams B, et al. Dietetic guidelines: Diet in secondary prevention of cardiovascular disease (first update, June 2003). Journal of Human Nutrition and Dietetics. 2004;17(4):337-349. Date of Publication: Aug 2004 2004;(4):337–49. [pmid: 15250843].
Horr R, Kieser M. Ginkgo biloba special extract EGb 761--an anti-dementia drug. [German]. Fortschr Med Orig. Jan. 30. 1998;116(3):39-40. [pmid: 9522547].
Hu YH, Li J, Wu NJ, et al. Clinical observation on effect of modified huanglian wendan dec 180 oction in treating diabetic asymptomatic myocardial ischemia. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Sep. 2005;25(9):790-3. [pmid: 16248239].
Huang CF, Li TC, Lin CC, et al. Efficacy of Monascus purpureus Went rice on lowering lipid ratios in hypercholesterolemic patients. Eur J Cardiovasc Prev Rehabil. Jun. 2007;14(3):438-40. [pmid: 17568245].
Jabbari A, Argani H, Ghorbanihaghjo A, et al. Comparison between swallowing and chewing of garlic on levels of serum lipids, cyclosporine, creatinine and lipid peroxidation in renal transplant recipients. Lipids health dis. 2005;4:11. [pmid: 15943877].
Jaxa-Chamiec T, Bednarz B, Drozdowska D, et al. Antioxidant effects of combined vitamins C and E in acute myocardial infarction. The randomized, double-blind, placebo controlled, multicenter pilot Myocardial Infarction and VITamins (MIVIT) trial. Kardiol Pol. Apr. 2005;62(4):344-50. [pmid: 16059992].
Jee SH, Miller ER III, Guallar E, et al. The effect of magnesium supplementation on blood pressure: a meta-analysis of randomized clinical trials. Am J Hypertens. Aug. 2002;15(8):691-6. [pmid: 12160191].
Jethmalani SM, Viswanathan G, Noronha JM. Effect of cod liver oil supplementation on plasma lipids, lipoproteins, lipase activity and platelet aggregation in normotensive and hypertensive volunteers. Indian J Exp Biol. Dec. 1989;27(12):1103-5. [pmid: 2633973].
Jie KS, Gijsbers BL, Knapen MH, et al. Effects of vitamin K and oral anticoagulants on urinary calcium excretion. Br J Haematol. Jan. 1993;83(1):100-4. [pmid: 8435316].
Jones PJ, Demonty I, Chan YM, et al. Fish-oil esters of plant sterols differ from vegetable-oil sterol esters in triglycerides lowering, carotenoid bioavailability and impact on plasminogen activator inhibitor-1 (PAI-1) concentrations in hypercholesterolemic subjects. Lipids in health and disease. 2007;6:28. [pmid: 17961204].
Jonkers IJ, Smelt AH, Princen HM, et al. Fish oil increases bile acid synthesis in male patients with hypertriglyceridemia. J Nutr. Apr. 2006;136(4):987-91. [pmid: 16549462].
Jorde R, Sneve M, Torjesen P, et al. Parameters of the thrombogram are associated with serum 25-hydroxyvitamin D levels at baseline, but not affected during supplementation with vitamin D. Thromb Res. May. 2010;125(5):e210-e213. [pmid: 20071011].
Judd SE, Raiser SN, Kumari M, et al. 1,25-dihydroxyvitamin D3 reduces systolic blood pressure in hypertensive adults: a pilot feasibility study. The Journal of steroid biochemistry and molecular biology. 2010;121(1–2):445-7. [pmid: 20420907].
Judd SE, Raiser SN, Kumari M, et al. 1,25-dihydroxyvitamin D3 reduces systolic blood pressure in hypertensive adults: a pilot feasibility study. J Steroid Biochem Mol Biol. Jul. 2010;121(1–2):445-7. [pmid: 20420907].
Jung EM, Jung F, Mrowietz C, et al. Influence of garlic powder on cutaneous microcirculation. A randomized placebo-controlled double-blind cross-over study in apparently healthy subjects. Arzneimittel Forschung. 1991;41(6):626-30. [pmid: 1930351].
Kalus U, Koscielny J, Grigorov A, et al. Improvement of cutaneous microcirculation and oxygen supply in patients with chronic venous insufficiency by orally administered extract of red vine leaves AS 195: a randomised, double-blind, placebo-controlled, crossover study. Drugs in R &D. 2004;5(2):63-71. [pmid: 15293865].
Kamikawa T, Kobayashi A, Yamashita T, et al. Effects of coenzyme Q10 on exercise tolerance in chronic stable angina pectoris. Am J Cardiol. Aug. 1. 1985;56(4):247-51. [pmid: 3927692].
Kampman E, Slattery ML, Caan B, et al. Calcium, vitamin D, sunshine exposure, dairy products and colon cancer risk (United States). Cancer Causes Control. May. 2000;11(5):459-66. [pmid: 10877339].
Kang JH, Cook NR, Manson JE, et al. Vitamin E, vitamin C, beta carotene, and cognitive function among women with or at risk of cardiovascular disease: The Women's Antioxidant and Cardiovas 1f40 cular Study. Circ Cardiovasc Qual Outcomes. Jun. 2. 2009;119(21):2772-80. [pmid: 19451353].
Kannar D, Wattanapenpaiboon N, Savige GS, et al. Hypocholesterolemic effect of an enteric-coated garlic supplement. J Am Coll Nutr. Jun. 2001;20(3):225-31. [pmid: 11444418].
Kanowski S, Herrmann WM, Stephan K, et al. Proof of efficacy of the ginkgo biloba special extract EGb 761 in outpatients suffering from mild to moderate primary degenerative dementia of the Alzheimer type or multi-infarct dementia. Pharmacopsychiatry. Mar. 1996;29(2):47-56. [pmid: 8741021].
Kappus H, Diplock AT. Tolerance and safety of vitamin E: a toxicological position report. [Review] [119 refs]. Free Radic Biol Med. 1992;13(1):55-74. [pmid: 1628854].
Kawano Y, Matsuoka H, Takishita S, et al. Effects of magnesium supplementation in hypertensive patients: assessment by office, home, and ambulatory blood pressures. Hypertension. Aug. 1998;32(2):260-5. [pmid: 9719052].
Kähler W, Kuklinski B, Rühlmann C, et al. Diabetes mellitus--a free radical-associated disease. Results of adjuvant antioxidant supplementation. Zeitschrift für die gesamte innere Medizin und ihre Grenzgebiete. 1993;48(5):223-32.
Keifer D, Ulbricht C, Abrams T, et al. Peppermint (Mentha xpiperita): An evidence-based systematic review by the Natural Standard Research Collaboration. J Herbal Pharmacother. 2007;7(2):91-143.
Keith ME, Jeejeebhoy KN, Langer A, et al. A controlled clinical trial of vitamin E supplementation in patients with congestive heart failure. Am J Clin Nutr. Feb. 2001;73(2):219-24. [pmid: 11157316].
Kelley DS, Siegel D, Vemuri M, et al. Docosahexaenoic acid supplementation decreases remnant-like particle-cholesterol and increases the (n-3) index in hypertriglyceridemic men. The Journal of nutrition. 2008;138(1):30-35. Date of Publication: Jan 2008 2008;(1):30–5. [pmid: 18156400].
Khan F, Elherik K, Bolton-Smith C, et al. The effects of dietary fatty acid supplementation on endothelial function and vascular tone in healthy subjects. Cardiovasc Res. Oct. 1. 2003;59(4):955-62. [pmid: 14553835].
Khan S, Minihane AM, Talmud PJ, et al. Dietary long-chain n-3 PUFAs increase LPL gene expression in adipose tissue of subjects with an atherogenic lipoprotein phenotype. J Lipid Res. Jun. 2002;43(6):979-85. [pmid: 12032174].
Kiesewetter H, Jung F, Pindur G, et al. Effect of garlic on thrombocyte aggregation, microcirculation, and other risk factors. Int J Clin Pharmacol Ther Toxicol. Apr. 1991;29(4):151-5. [pmid: 2071264].
Kiesewetter H, Jung F, Jung EM, et al. Effects of garlic coated tablets in peripheral arterial occlusive disease. Clin Investig. May. 1993;71(5):383-6. [pmid: 8508009].
Kim EJ, Kim HJ, Kim SG, et al. Aloe-induced Henoch-Schonlein purpura. Nephrology. Feb. 2007;12(1):109. [pmid: 17295672].
Kim SH, Park KS. Effects of Panax ginseng extract on lipid metabolism in humans. Pharmacol Res. Nov. 2003;48(5):511-3. [pmid: 12967598].
Kim SH, Lee EK, Chang JW, et al. Effects of Ginkgo biloba on haemostatic factors and inflammation in chronic peritoneal dialysis patients. PHYTOTHER RES. Jun. 2005;19(6):546-8. [pmid: 16114087].
Kim SY, Song HJ, Lee YY, et al. Biomedical issues of dietary fiber beta-glucan. [Review] [74 refs]. J Korean Med Sci. Oct. 2006;21(5):781-9. [pmid: 17043406].
Klein K. Vasoactive combination treatment in cerebrovascular sclerosis. [German]. Wien Med Wochenschr. Jan. 6. 1973;123(1):14-8. [pmid: 4405190].
Knapp HR, Reilly IA, Alessandrini P, et al. In vivo indexes of platelet and vascular function during fish-oil administration in patients with atherosclerosis. N Engl J Med. Apr. 10. 1986;314(15):937-42. [pmid: 3007982].
Knapp HR, FitzGerald GA. The antihypertensive effects of fish oil. A controlled study of polyunsaturated fatty acid supplements in essential hypertension. N Engl J Med. Apr. 20. 1989;320(16):1037-43. [pmid: 2648152].
Knipscheer HC, Kindt I, van den Ende A, et al. Magnesium pyridoxal-5′-phosphate glutamate, "A vitamin B6 derivative", does not affect lipoprotein levels in patients with familial hypercholesterolaemia. Eur J Clin Pharmacol. 1997;51(6):499-503. [pmid: 9112067].
Knox J, Gaster B. Dietary supplements for the prevention and treatment of coronary artery disease. [Review] [145 refs]. J Altern Complement Med. Jan. 2007;13(1):83-95. [pmid: 17309382].
Kobayashi K, Hamazaki K, Fujioka S, et al. The effect of n-3 PUFA/-cyclodextrin complex on serum lipids in healthy volunteers - A randomized, placebo-controlled, double-blind trial. Asia Pacific Journal of Clinical Nutrition. 2007;16(3):429-434. Date of Publication: September 2007 2007;(3):429–34. [pmid: 17704023].
Kothny W, Angerer P, Störk S, et al. Short term effects of omega-3 fatty acids on the radial artery of patients with coronary artery disease. Atherosclerosis. Sep. 1998;140(1):181-6. [pmid: 9733230].
Kris-Etherton PM, Lichtenstein AH, Howard BV, et al. Antioxidant vitamin supplements and cardiovascular disease. [Review] [33 refs]. Circ Cardiovasc Qual Outcomes. Aug. 3. 2004;110(5):637-41. [pmid: 15289389].
Kristensen SD, Schmidt EB, Andersen HR, et al. Fish oil in angina pectoris. Atherosclerosis. Mar. 1987;64(1):13-9. [pmid: 3109445].
Kristensen SD, Schmidt EB, Dyerberg J. Dietary supplementation with n-3 polyunsaturated fatty acids and human platelet function: a review with particular emphasis on implications for cardiovascular disease. [Review] [97 refs]. J Intern Med. Supplement. 731. 1989:141-50. [pmid: 2650690].
Kudolo GB. The effect of 3-month ingestion of Ginkgo biloba extract (EGb 761) on pancreatic beta-cell function in response to glucose loading in individuals with non-insulin-dependent diabetes mellitus. J Clin Pharmacol. Jun. 2001;41(6):600-11. [pmid: 11402628].
Kudolo GB, Wang W, Elrod R, et al. Short-term ingestion of Ginkgo biloba extract does not alter whole body insulin sensitivity in non-diabetic, pre-diabetic or type 2 diabetic subjects--a randomized double-blind placebo-controlled crossover study. Clinical nutrition (Edinburgh, Scotland). 2006;25(1):123-34.
Kugiyama K, Motoyama T, Doi H, et al. Improvement of endothelial vasomotor dysfunction by treatment with alpha-tocopherol in patients with high remnant lipoproteins levels. J Am Coll Cardiol. May. 1999;33(6):1512-8. [pmid: 10334416].
Lamon-Fava S, Diffenderfer MR, Barrett PH, et al. Extended-release niacin alters the metabolism of plasma apolipoprotein (Apo) A-I and ApoB-containing lipoproteins. Arterioscler Thromb Vasc Biol. Sep. 2008;28(9):1672-8. [pmid: 18566298].
Landahl S, Graffner C, Jagenburg R. Prevalence and treatment of hypomagnesemia in the elderly. Studies of a representative 70-year-old population and of geriatric patients. Aktuel Gerontol. 1980;10(9):397-402. [pmid: 6110376].
Langsjoen PH, Vadhanavikit S, Folkers K. Response of patients in classes III and IV of cardiomyopathy to therapy in a blind and crossover trial with coenzyme Q10. Proc Natl Acad Sci U S A. Jun. 1985;82(12):4240-4. [pmid: 3858877].
Langsjoen PH, Langsjoen AM. Supplemental ubiquinol in patients with advanced congestive heart failure. Biofactors. 2008;32(1–4):119-28. [pmid: 19096107].
Lash JP, Cardoso LR, Mesler PM, et al. The effect of garlic on hypercholesterolemia in renal transplant patients. Transplantation Proceedings. 1998;30(1):189-191. Date of Publication: 1998 1998;(1):189–91. [pmid: 9474997].
Le Bars PL, Katz MM, Berman N, et al. A placebo-controlled, double-blind, randomized trial of an extract of Ginkgo biloba for dementia. North American EGb Study Group. J Am Med Assoc. Oct. 22. 1997;278(16):1327-32. [pmid: 9343463].
Le Bars PL, Kieser M, Itil KZ. A 26-week analysis of a double-blind, placebo-controlled trial of the ginkgo biloba extract EGb 761 in dementia. Dement Geriatr Cogn Disord. Jul. 2000;11(4):230-7. [pmid: 10867450].
Leaf A, Albert CM, Josephson M, et al. Prevention of fatal arrhythmias in high-risk subjects by fish oil n-3 fatty acid intake. Circ Cardiovasc Qual Outcomes. Nov. 1. 2005;112(18):2762-8. [pmid: 16267249].
Lee Y-J, Cho W-J, Kim J-K, et al. Effects of coenzyme Q10 on arterial stiffness, metabolic parameters, and fatigue in obese subjects: A double-blind randomized controlled study. J med food. 2011;14(4):386-90. [pmid: 21370966].
Lekakis J, Rallidis LS, Andreadou I, et al. Polyphenolic compounds from red grapes acutely improve endothelial function in patients with coronary heart disease. Eur J Cardiovasc Prev Rehabil. Dec. 2005;12(6):596-600. [pmid: 16319551].
Leppälä JM, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arteriosclerosis, thrombosis, and vascular biology. 2000;20(1):230-5.
Lepre F, Campbell B, Crane S, et al. Low-dose sustained release nicotinic acid (Tri-B3) and lipoprotein (a). Am J Cardiol. Jul. 1. 1992;70(1):133. [pmid: 1535476].
Leuchtgens H. Crataegus Special Extract WS 1442 in NYHA II heart failure. A placebo controlled randomized double-blind study. [German]. Fortschr Med Orig. Jul. 20. 1993;111(20–21):352-4. [pmid: 8375791].
Lev EI, Solodky A, Harel N, et al. Treatment of aspirin-resistant patients with omega-3 fatty acids versus aspirin dose escalation. J Am Coll Cardiol. Jan. 12. 2010;55(2):114-21. [pmid: 20117379].
Lev EI, Solodky A, Harel N, et al. Treatment of aspirin-resistant patients with omega-3 fatty acids versus aspirin dose escalation. J Am Coll Cardiol. 2010;55(2):114-21. [pmid: 20117379].
Levinson PD, Iosiphidis AH, Saritelli AL, et al. Effects of n-3 fatty acids in essential hypertension. Am J Hypertens. Oct. 1990;3(10):754-60. [pmid: 2222942].
Levy AP, Blum S. Pharmacogenomics in prevention of diabetic cardiovascular disease: utilization of the haptoglobin genotype in determining benefit from vitamin E. [Review] [45 refs]. Expert Rev Cardiovasc Ther. Nov. 2007;5(6):1105-11. [pmid: 18035926].
Levy H. The problem of an antilipemic synergism between the action of nicotinic acid and the sulphated polyanion SP54 (author's transl). [German]. Med Klin. Sep. 6. 1974;69(36):1441-7. [pmid: 4280008].
Li J, Zhang Q, Zhang M, et al. Intravenous magnesium for acute myocardial infarction. [Review] [67 refs][Update of J Mol Evol. 2003 Oct;57(4):453–66; PMID:14708578]. Cochrane Database Syst Rev. 2007;(2):CD002755. [pmid: 17443517].
Li JJ, Wang Y, Nie SP, et al. Xuezhikang, an extract of cholestin, decreases plasma inflammatory markers and endothelin-1, improve exercise-induced ischemia and subjective feelings in patients with cardiac syndrome X. Int J Cardiol. Oct. 31. 2007;122(1):82-4. [pmid: 17196275].
Li SQ, Yuan RX, Gao H. Clinical observation on the treatment of ischemic heart disease with Astragalus membranaceus. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Feb. 1995;15(2):77-80. [pmid: 7787395].
Lichodziejewska B, Klo&#x015B J, et al. Clinical symptoms of mitral valve prolapse are related to hypomagnesemia and attenuated by magnesium supplementation. Am J Cardiol. Mar. 15. 1997;79(6):768-72. [pmid: 9070556].
Lichtenstein AH, Matthan NR, Jalbert SM, et al. Novel soybean oils with different fatty acid profiles alter cardiovascular disease risk factors in moderately hyperlipidemic subjects. The American journal of clinical nutrition. 2006;84(3):497-504. [pmid: 16960162].
Liem A, Reynierse-Buitenwerf GH, Zwinderman AH, et al. Secondary prevention with folic acid: effects on clinical outcomes. J Am Coll Cardiol. Jun. 18. 2003;41(12):2105-13. [pmid: 12821232].
Lin J, Cook NR, Lee IM, et al. Total magnesium intake and colorectal cancer incidence in women. Cancer Epidemiol Biomarkers Prev. Oct. 2006;15(10):2006-9. [pmid: 17035414].
Lind L, Wengle B, Wide L, et al. Hypertension in primary hyperparathyroidism--reduction of blood pressure by long-term treatment with vitamin D (alphacalcidol). A double-blind, placebo-controlled study. Am J Hypertens. Oct. 1988;1(4 Pt 1):397-402. [pmid: 3063290].
Lind L, Wengle B, Wide L, et al. Reduction of blood pressure during long-term treatment with active vitamin D (alphacalcidol) is dependent on plasma renin activity and calcium status. A double-blind, placebo-controlled study. Am J Hypertens. Jan. 1989;2(1):20-5. [pmid: 2643969].
Lind L, Wengle B, Lithell H, et al. No major metabolic alterations accompany the hypotensive effect of active vitamin D. Ups J Med Sci. 1991;96(3):199-204. [pmid: 1810079].
Lind L, Lithell H, Pollare T, et al. Blood pressure response during long-term treatment with magnesium is dependent on magnesium status. A double-blind, placebo-controlled study in essential hypertension and in subjects with high-normal blood pressure. Am J Hypertens. Aug. 1991;4(8):674-9. [pmid: 1930849].
Lindman AS, Pedersen JI, Hjerkinn EM, et al. The effects of long-term diet and omega-3 fatty acid supplementation on coagulation factor VII and serum phospholipids with special emphasis on the R353Q polymorphism of the FVII gene. Thromb Haemost. Jun. 2004;91(6):1097-104. [pmid: 15175795].
Liu M, Wallmon A, Olsson-Mortlock C, et al. Mixed tocopherols inhibit platelet aggregation in humans: potential mechanisms. Am J Clin Nutr. Mar. 2003;77(3):700-6. [pmid: 12600864].
Liu X, Du J, Cai J, et al. Clinical systematic observation of Kangxin capsule curing vascular dementia of senile kidney deficiency and blood stagnation type. J Ethnopharmacol. Jun. 13. 2007;112(2):350-5. [pmid: 17442512].
Lofgren RP, Wilt TJ, Nichol KL, et al. The effect of fish oil supplements on blood pressure. Am J Public Health. Feb. 1993;83(2):267-9. [pmid: 8427339].
Lonn EM, Yusuf S. Is there a role for antioxidant vitamins in the prevention of cardiovascular diseases? An update on epidemiological and clinical trials data. Can J Cardiol. Oct. 1997;13(10):957-65. [pmid: 9374952].
Losonczy KG, Harris TB, Havlik RJ. Vitamin E and vitamin C supplement use and risk of all-cause and coronary heart disease mortality in older persons: the Established Populations for Epidemiologic Studies of the Elderly. Am J Clin Nutr. Aug. 1996;64(2):190-6. [pmid: 8694019].
Reşatoğlu AG, Uymaz OK, Akbulut B, et al. Supplementation of magnesium to warm blood hyperkalemic cardioplegia for the prevention of atrial fibrillation after coronary artery bypass grafting. Anadolu Kardiyol Derg. Jun. 2007;7(2):230. [pmid: 17513237].
Lungershausen YK, Abbey M, Nestel PJ, et al. Reduction of blood pressure and plasma triglycerides by omega-3 fatty acids in treated hypertensives. J Hypertens. Sep. 1994;12(9):1041-5. [pmid: 7852747].
Luo S, Wang X, Kuang P. A clinical study of Yangxueqingnaokeli in preventive treament of migraine. Chinese Journal of Neurology. 2001;34(5):291-4.
Luo XX, Duan JG, Liao PZ, et al. Effect of qiming granule on retinal blood circulation of diabetic retinopathy: a multicenter clinical trial. Chin J Integr Med. Oct. 2009;15(5):384-8. [pmid: 19802544].
Lysakowski C, Von EE, Dumont L, et al. Effect of magnesium, high altitude and acute mountain sickness on blood flow velocity in the middle cerebral artery. Clin Sci (Colch). Mar. 2004;106(3):279-85. [pmid: 14572304].
Mabile L, Bruckdorfer KR, Rice-Evans C. Moderate supplementation with natural alpha-tocopherol decreases platelet aggregation and low-density lipoprotein oxidation. Atherosclerosis. Nov. 1. 1999;147(1):177-85. [pmid: 10525139].
Mackness MI, Bhatnagar D, Durrington PN, et al. Effects of a new fish oil concentrate on plasma lipids and lipoproteins in patients with hypertriglyceridaemia. Eur J Clin Nutr. Dec. 1994;48(12):859-65. [pmid: 7889894].
Madden J, Brunner A, Dastur ND, et al. Fish oil induced increase in walking distance, but not ankle brachial pressure index, in peripheral arterial disease is dependent on both body mass index and inflammatory genotype. Prostaglandins Leukot Essent Fatty Acids. Jun. 2007;76(6):331-40. [pmid: 17600695].
Magliano D, McNeil J, Branley P, et al. The Melbourne Atherosclerosis Vitamin E Trial (MAVET): a study of high dose vitamin E in smokers. Eur J Cardiovasc Prev Rehabil. Jun. 2006;13(3):341-7. [pmid: 16926662].
Marchioli R, Schweiger C, Tavazzi L, et al. Efficacy of n-3 polyunsaturated fatty acids after myocardial infarction: results of GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico. Lipids. Suppl. 2001;36:S119-126. [pmid: 11837985].
Margolin G, Huster G, Glueck CJ, et al. Blood pressure lowering in elderly subjects: a double-blind crossover study of omega-3 and omega-6 fatty acids. Am J Clin Nutr. Feb. 1991;53(2):562-72. [pmid: 1989427].
Marik PE, Varon J. Omega-3 dietary supplements and the risk of cardiovascular events: a systematic review. [Review] [59 refs]. Clin Cardiol. Jul. 2009;32(7):365-72. [pmid: 19609891].
Marrugat J, Covas MI, Fitó M, et al. Effects of differing phenolic content in dietary olive oils on lipids and LDL oxidation--a randomized controlled trial. Eur J Nutr. 2004;43(3):140-7. [pmid: 15168036].
Matvienko OA, Lewis DS, Swanson M, et al. A single daily dose of soybean phytosterols in ground beef decreases serum total cholesterol and LDL cholesterol in young, mildly hypercholesterolemic men. American Journal of Clinical Nutrition. 2002;76(1):57-64. Date of Publication: 2002 2002;(1):57–64. [pmid: 12081816].
McCarthy GM, Kenny D. Dietary fish oil and rheumatic diseases. [Review] [70 refs]. Semin Arthritis Rheum. Jun. 1992;21(6):368-75. [pmid: 1626282].
McGrath LT, Brennan GM, Donnelly JP, et al. Effect of dietary fish oil supplementation on peroxidation of serum lipids in patients with non-insulin dependent diabetes mellitus. Atherosclerosis. 1996;121(2):275-83. [pmid: 9125301].
McKenney JM, McCormick LS, Schaefer EJ, et al. Effect of niacin and atorvastatin on lipoprotein subclasses in patients 1f40 with atherogenic dyslipidemia. Am J Cardiol. Aug. 1. 2001;88(3):270-4. [pmid: 11472706].
McKeone BJ, Osmundsen K, Brauchi D, et al. Alterations in serum phosphatidylcholine fatty acyl species by eicosapentaenoic and docosahexaenoic ethyl esters in patients with severe hypertriglyceridemia. J Lipid Res. Mar. 1997;38(3):429-36. [pmid: 9101424].
McMackin CJ, Widlansky ME, Hamburg NM, et al. Effect of combined treatment with alpha-Lipoic acid and acetyl-L-carnitine on vascular function and blood pressure in patients with coronary artery disease. J Clin Hypertens (Greenwich). Apr. 2007;9(4):249-55. [pmid: 17396066].
Mcrae MP. Is vitamin C an effective antihypertensive supplement: a review and analysis of the literature (DARE structured abstract). Journal of Chiropractic Medicine. 2006;5:60-4. [pmid: 19674673].
McSorley PT, Bell PM, Young IS, et al. Endothelial function, insulin action and cardiovascular risk factors in young healthy adult offspring of parents with Type 2 diabetes: effect of vitamin E in a randomized double-blind, controlled clinical trial. Diabet Med. Jun. 2005;22(6):703-10. [pmid: 15910620].
McVeigh GE, Brennan GM, Johnston GD, et al. Dietary fish oil augments nitric oxide production or release in patients with type 2 (non-insulin-dependent) diabetes mellitus. Diabe 1f40 tologia. Jan. 1993;36(1):33-8. [pmid: 8436250].
Meese RB, Gonzales DG, Casparian JM, et al. The inconsistent effects of calcium supplements upon blood pressure in primary hypertension. Am J Med Sci. Oct. 1987;294(4):219-24. [pmid: 3310639].
Melzer J, Saller R. Hawthorn (Crataegus) in Heart Failure: A review. Schweiz Z Ganzheits Medizin. Oct. 2005;17(6):362-6.
MEND-CABG Investigators. Alexander JH, Emery RW Jr, et al. Efficacy and safety of pyridoxal 5′-phosphate (MC-1) in high-risk patients undergoing coronary artery bypass graft surgery: the MEND-CABG II randomized clinical trial. J Am Med Assoc. Apr. 16. 2008;299(15):1777-87. [pmid: 18381567].
Merkel M. Diabetic dyslipoproteinemia: beyond LDL. [Review] [54 refs] [German]. Dtsch Med Wochenschr. May. 2009;134(20):1067-73. [pmid: 19421932].
Micallef MA, Garg ML. Anti-inflammatory and cardioprotective effects of n-3 polyunsaturated fatty acids and plant sterols in hyperlipidemic individuals. Atherosclerosis. Jun. 2009;204(2):476-82. [pmid: 18977480].
Miller ER III, Pastor-Barriuso R, Dalal D, et al. Meta-analysis: High-dosage vitamin E supplementation may increase all-cause mortality. Annals of Internal Medicine. 46+I. 2005;142(1):37-40. Date of Publication: 04 Jan 2005 2005;(1):37–40. [pmid: 15537682].
Miller HI, Dascalu A, Rassin TA, et al. Effects of an acute dose of L-arginine during coronary angiography in patients with chronic renal failure: a randomized, parallel, double-blind clinical trial. Am J Nephrol. Mar. 2003;23(2):91-5. [pmid: 12481147].
Miller S, Crystal E, Garfinkle M, et al. Effects of magnesium on atrial fibrillation after cardiac surgery: a meta-analysis. Heart. May. 2005;91(5):618-23. [pmid: 15831645].
Mills DE, Prkachin KM. Psychological stress reverses antiaggregatory effects of dietary fish oil. J Behav Med. Aug. 1993;16(4):403-12. [pmid: 8411145].
Mills E, Montori VM, Wu P, et al. Interaction of St John's wort with conventional drugs: Systematic review of clinical trials. Br Med J. 2004;329(7456):27-30. [pmid: 15231618].
Misso NLA, Thompson PJ. Fish oil supplementation inhibits platelet aggregation and ATP release induced by platelet-activating factor and other agonists. Platelets. 1995;6(5):275-82. [pmid: 21043713].
Miyajima T, Tsujino T, Saito K, et al. Effects of eicosapentaenoic acid on blood pressure, cell membrane fatty acids, and intracellular sodium concentration in essential hypertension. Hypertens Res. Sep. 2001;24(5):537-42. [pmid: 11675948].
Mizushima S, Cappuccio FP, Nichols R, et al. Dietary magnesium intake and blood pressure: a qualitative overview of the observational studies. J Hum Hypertens. Jul. 1998;12(7):447-53. [pmid: 9702930].
Mohammed S, Goodacre S. Intravenous and nebulised magnesium sulphate for acute asthma: systematic review and meta-analysis. [Review] [39 refs]. Emerg Med J. Dec. 2007;24(12):823-30. [pmid: 18029512].
Morgan DR, Dixon LJ, Hanratty CG, et al. Effects of dietary omega-3 fatty acid supplementation on endothelium-dependent vasodilation in patients with chronic heart failure. Am J Cardiol. Feb. 15. 2006;97(4):547-51. [pmid: 16461054].
Mori TA, Beilin LJ, Burke V, et al. Interactions between dietary fat, fish, and fish oils and their effects on platelet function in men at risk of cardiovascular disease. Arterioscler Thromb Vasc Biol. Feb. 1997;17(2):279-86. [pmid: 9081682].
Mori TA, Watts GF, Burke V, et al. Differential effects of eicosapentaenoic acid and docosahexaenoic acid on vascular reactivity of the forearm microcirculation in hyperlipidemic, overweight men. Circ Cardiovasc Qual Outcomes. Sep. 12. 2000;102(11):1264-9. [pmid: 10982541].
Mori TA, Woodman RJ, Burke V, et al. Effect of eicosapentaenoic acid and docosahexaenoic acid on oxidative stress and inflammatory markers in treated-hypertensive type 2 diabetic subjects. Free Radical Biology and Medicine. 2003;35(7):772-781. Date of Publication: 01 Oct 2003 2003;(7):772–81. [pmid: 14583341].
Morisco C, Nappi A, Argenziano L, et al. Noninvasive evaluation of cardiac hemodynamics during exercise in patients with chronic heart failure: effects of short-term coenzyme Q10 treatment. Mol Aspects Med. Suppl. 1994;15:s155-s163. [pmid: 7752827].
Morris CD, Carson S. Routine vitamin supplementation to prevent cardiovascular disease: a summary of the evidence for the U. S Preventive Services Task Force. Ann Intern Med. Jul. 1. 2003;139(1):56-70. [pmid: 12834320].
Morris MC, Taylor JO, Stampfer MJ, et al. The effect of fish oil on blood pressure in mild hypertensive subjects: a randomized crossover trial. Am J Clin Nutr. Jan. 1993;57(1):59-64. [pmid: 8416666].
Mortensen SA, Vadhanavikit S, Baandrup U, et al. Long-term coenzyme Q10 therapy: a major advance in the management of resistant myocardial failure. Drugs Exp Clin Res. 1985;11(8):581-93. [pmid: 3836876].
Moruisi KG, Oosthuizen W, Opperman AM. Phytosterols/stanols lower cholesterol concentrations in familial hypercholesterolemic subjects: a systematic review with meta-analysis. [Review] [43 refs]. J Am Coll Nutr. Feb. 2006;25(1):41-8. [pmid: 16522931].
Munkholm H, Hansen HH, Rasmussen K. Coenzyme Q10 treatment in serious heart failure. Biofactors. 1999;9(2–4):285-9. [pmid: 10416042].
Myers MG. Caffeine and cardiac arrhythmias. [Review] [23 refs]. Ann Intern Med. Jan. 15. 1991;114(2):147-50. [pmid: 1984393].
Myrup B, Rossing P, Jensen T, et al. Lack of effect of fish oil supplementation on coagulation and transcapillary escape rate of albumin in insulin-dependent diabetic patients with diabetic nephropathy. Scand J Clin Lab Invest. 2001;61(5):349-56. [pmid: 11569481].
Nagyová A, Mongiellová V, Krivosíková Z, et al. Serum ex vivo lipoprotein oxidizability in patients with ischemic heart disease supplemented with vitamin E. Physiological research/Academia Scientiarum Bohemoslovaca. 2002;51(5):457-64. [pmid: 12470198].
Neil A, Silagy C. Garlic: its cardio-protective properties. [Review] [43 refs]. Curr Opin Lipidol. Feb. 1994;5(1):6-10. [pmid: 15559024].
Ness AR, Powles JW, Khaw KT. Vitamin C and cardiovascular disease: a systematic review. J Cardiovasc Risk. Dec. 1996;3(6):513-21. [pmid: 9100087].
Neunteufl T, Priglinger U, Heher S, et al. Effects of vitamin E on chronic and acute endothelial dysfunction in smokers. J Am Coll Cardiol. Feb. 2000;35(2):277-83. [pmid: 10676670].
Neves PL, Malho A, Cabrita A, et al. Statins and vitamin D: a friendly association in pre-dialysis patients. Int Urol Nephrol. Mar. 2010;42(1):173-9. [pmid: 19763871].
Ngamjarus C, Pattanittum P, Somboonporn C. Roselle for hypertension in adults. [Review] [22 refs]. Cochrane Database Syst Rev. 2010;(1):CD007894. [pmid: 20091658].
Ngamjarus C, Pattanittum P, Somboonporn C. Roselle for hypertension in adults [Cochrane review]. Cochrane Database of Systematic Reviews 2010. Chichester (UK). John Wiley & Sons, Ltd. 2010;(1):1.
NICE. Post myocardial infarction secondary prevention in primary and secondary care for patients following a myocardial infarction. National Institute for Health and Clinical Excellence. 2007.
Nicolaï S, Gerardu VC, Kruidenier LM, et al. From the Cochrane library: Ginkgo biloba for intermittent claudication. Vasa. May. 2010;39(2):153-8. [pmid: 20464671].
Niittynen LH, Jauhiainen TA, Poussa TA, et al. Effects of yoghurt enriched with free plant sterols on the levels of serum lipids and plant sterols in moderately hypercholesterolaemic subjects on a high-fat diet. Int J Food Sci Nutr. Aug. 2008;59(5):357-67. [pmid: 18979616].
Nilsen DW, Dalaker K, Nord&#x00F8, et al. Influence of a concentrated ethylester compound of n-3 fatty acids on lipids, platelets and coagulation in patients undergoing coronary bypass surgery. Thromb Haemost. Aug. 1. 1991;66(2):195-201. [pmid: 1771612].
Nowson CA, Morgan TO. Magnesium supplementation in mild hypertensive patients on a moderately low sodium diet. Clin Exp Pharmacol Physiol. Apr. 1989;16(4):299-302. [pmid: 2663263].
Nye ER, Ablett MB, Robertson MC, et al. Effect of eicosapentaenoic acid on restenosis rate, clinical course and blood lipids in patients after percutaneous transluminal coronary angioplasty. Aust N Z J Med. Aug. 1990;20(4):549-52. [pmid: 2222347].
O'Keefe J, Abuissa H, Sastre A, et al. Effects of Omega-3 Fatty Acids on Resting Heart Rate, Heart Rate Recovery After Exercise, and Heart Rate Variability in Men With Healed Myocardial Infarctions and Depressed Ejection Fractions. American Journal of Cardiology. 2006;97(8):1127-1130. Date of Publication: 15 Apr 2006 2006;(8):1127–30. [pmid: 16616012].
Obel AO. Placebo-controlled trial of potassium supplements in black patients with mild essential hypertension. J Cardiovasc Pharmacol. Aug. 1989;14(2):294-6. [pmid: 2476604].
Oda T. Recovery of load-induced left ventricular diastolic dysfunction by coenzyme Q10: echocardiographic study. Mol Aspects Med. Suppl. 1994;15:s149-s154. [pmid: 7752826].
Ogawa T, Ishida H, Akamatsu M, et al. Relation of oral 1alpha-hydroxy vitamin D3 to the progression of aortic arch calcification in hemodialysis patients. Heart Vessels. Jan. 2010;25(1):1-6. [pmid: 20091391].
Oguntibeju OO, Van Den Heever WMJ, Van Schalkwyk FE. Supplementation effect on Body Weight and BMI of HIV-positive/AIDS patients. International Journal of Pharmacology. 2007;3(1):120-2.
Oktar GL, Sinci V, Kalaycioglu S, et al. Biochemical and hemodynamic effects of ascorbic acid and alpha-tocopherol in coronary artery surgery. Scand J Clin Lab Invest. 2001;61(8):621-9. [pmid: 11768322].
Paech MJ, Magann EF, Doherty DA, et al. Does magnesium sulfate reduce the short- and long-term requirements for pain relief after caesarean delivery? A double-blind placebo-controlled trial. Am J Obstet Gynecol. Jun. 2006;194(6):1596-602. [pmid: 16615926].
Pal S, Ellis V, Dhaliwal S. Effects of whey protein isolate on body composition, lipids, insulin and glucose in overweight and obese individuals. Br J Nutr. Sep. 2010;104(5):716-23. [pmid: 20377924].
Paradisi G, Cucinelli F, Mele MC, et al. Endothelial function in post-menopausal women: effect of folic acid supplementation. Hum Reprod. Apr. 2004;19(4):1031-5. [pmid: 15016776].
Park Y, Harris WS. Omega-3 fatty acid supplementation accelerates chylomicron triglyceride clearance. J Lipid Res. Mar. 2003;44(3):455-63. [pmid: 12562865].
Park Y, Jones PG, Harris WS. Triacylglycerol-rich lipoprotein margination: a potential surrogate for whole-body lipoprotein lipase activity and effects of eicosapentaenoic and docosahexaenoic acids. Am J Clin Nutr. Jul. 2004;80(1):45-50. [pmid: 15213026].
Pase MP, Grima NA, Sarris J. The effects of dietary and nutrient interventions on arterial stiffness: a systematic review. [Review]. Am J Clin Nutr. Feb. 2011;93(2):446-54. [pmid: 21147858].
Passfall J, Philipp T, Woermann F, et al. Different effects of eicosapentaenoic acid and olive oil on blood pressure, intracellular free platelet calcium, and plasma lipids in patients with essential hypertension. The Clinical investigator. 1993;71(8):628-33. [pmid: 8219660].
Patra KK, Coffey CE. Implications of herbal alternative medicine for electroconvulsive therapy. J ECT. 2004;20(3):186-94. [pmid: 15343004].
Paul N, John G. Nebulised salbutamol and magnesium sulphate in acute asthma. La 1f40 ncet. Sep. 27. 2003;362(9389):1079. [pmid: 14522548].
Peet M. Eicosapentaenoic acid in the treatment of schizophrenia and depression: rationale and preliminary double-blind clinical trial results. Prostaglandins Leukot Essent Fatty Acids. Dec. 2003;69(6):477-85. [pmid: 14623502].
Peters H, Kieser M, Hölscher U. Demonstration of the efficacy of ginkgo biloba special extract EGb 761 on intermittent claudication--a placebo-controlled, double-blind multicenter trial. Vasa. May. 1998;27(2):106-10. [pmid: 9612115].
Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D_3_ and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. Journal of Clinical Endocrinology and Metabolism. 2001;86(4):1633-1637. Date of Publication: 2001 2001;(4):1633–7. [pmid: 11297596].
Pham DQ, Plakogiannis R. Vitamin E supplementation in cardiovascular disease and cancer prevention: Part 1. Ann Pharmacother. Nov. 2005;39(11):1870-8. [pmid: 16189282].
Philipp CS, Cisar LA, Saidi P, et al. Effect of niacin supplementation on fibrinogen levels in patients with peripheral vascular disease. Am J Cardiol. Sep. 1. 2009;82(5):697-9. [pmid: 9732910].
Phung OJ, Baker WL, Matthews LJ, et al. Effect of green tea catechins with or without caffeine on anthropometric measures: a systematic review and meta-analysis. [Review] [43 refs]. Am J Clin Nutr. Jan. 2010;91(1):73-81. [pmid: 19906797].
Piatti P, Fragasso G, Monti LD, et al. Acute intravenous L-arginine infusion decreases endothelin-1 levels and improves endothelial function in patients with angina pectoris and normal coronary arteriograms: correlation with asymmetric dimethylarginine levels. Circ Cardiovasc Qual Outcomes. Jan. 28. 2003;107(3):429-36. [pmid: 12551867].
Pietri S, Séguin JR, d'Arbigny P, et al. Ginkgo biloba extract (EGb 761) pretreatment limits free radical-induced oxidative stress in patients undergoing coronary bypass surgery. Cardiovascular drugs and therapy/sponsored by the International Society of Cardiovascular Pharmacotherapy. 1997;11(2):121-31. [pmid: 9140689].
Pirich C, Gaszo A, Granegger S, et al. Effects of fish oil supplementation on platelet survival and ex vivo platelet function in hypercholesterolemic patients. Thromb Res. Nov. 1. 1999;96(3):219-27. [pmid: 10588465].
Pittler MH, Thompson CO, Ernst E. Artichoke leaf extract for treating hypercholesterolaemia. Cochrane Database Syst Rev. 2002;(3):CD003335. [pmid: 12137691].
Pittler MH, Schmidt K, Ernst E. Hawthorn extract for treating chronic heart failure: meta-analysis of randomized trials. Am J Med. Jun. 1. 2003;114(8):665-74. [pmid: 12798455].
Pittler MH, Ernst E. Complementary therapies for reducing body weight: a systematic review. [Review] [77 refs]. Int J Obes (Lond). Sep. 2005;29(9):1030-8. [pmid: 15925954].
Pratt CM, Reiffel JA, Ellenbogen KA, et al. Efficacy and safety of prescription omega-3-acid ethyl esters for the prevention of recurrent symptomatic atrial fibrillation: a prospective study. Am Heart J. Aug. 2009;158(2):163-9. [pmid: 19619690].
Preiss D, Sattar N. Lipids, lipid modifying agents and cardiovascular risk: a review of the evidence. [Review] [111 refs]. Clin Endocrinol (Oxf). Jun. 2009;70(6):815-28. [pmid: 19067719].
Preuss HG, Bagchi D, Bagchi M, et al. Effects of a natural extract of (−)-hydroxycitric acid (HCA-SX) and a combination of HCA-SX plus niacin-bound chromium and Gymnema sylvestre extract on weight loss. Diabetes Obes Metab. May. 2004;6(3):171-80. [pmid: 15056124].
Prisco D, Paniccia R, Bandinelli B, et al. Effect of medium-term supplementation with a moderate dose of n-3 polyunsaturated fatty acids on blood pressure in mild hypertensive patients. Thromb Res. Aug. 1. 1998;91(3):105-12. [pmid: 9733153].
Proctor ML, Murphy PA. Herbal and dietary therapies for primary and secondary dysmenorrhoea. [Review] [40 refs]. Cochrane Database Syst Rev. 2001;(3):CD002124. [pmid: 11687013].
Proudman SM, Cleland LG, James MJ. Dietary Omega-3 Fats for Treatment of Inflammatory Joint Disease: Efficacy and Utility. Rheumatic Disease Clinics of North America. 2008;34(2):469-79. [pmid: 18638687].
Prousky J, Seely D. The treatment of migraines and tension-type headaches with intravenous and oral niacin (nicotinic acid): systematic review of the literature. [Review] [43 refs]. Nutr J. 2005;4:3. [pmid: 15673472].
Puhakainen I, Ahola I, Yki-Järvinen H. Dietary supplementation with n-3 fatty acids increases gluconeogenesis from glycerol but not hepatic glucose production in patients with non-insulin-dependent diabetes mellitus. The American journal of clinical nutrition. 1995;61(1):121-6. [pmid: 7825523].
Qureshi AA, Qureshi N, Wright JJ, et al. Lowering of serum cholesterol in hypercholesterolemic humans by tocotrienols (palmvitee). Am J Clin Nutr. Apr. 1991;53(4 Suppl):1021S-6S. [pmid: 2012010].
Raabe A, Raabe M, Ihm P. Therapeutic follow-up using automatic perimetry in chronic cerebroretinal ischemia in elderly patients. Prospective double-blind study with graduated dose ginkgo biloba treatment (EGb 761). [German]. Klin Monatsbl Augenheilkd 1f40. Dec. 1991;199(6):432-8. [pmid: 1791685].
Racek J, Rusnakova H, Trefil L, et al. The influence of folate and antioxidants on homocysteine levels and oxidative stress in patients with hyperlipidemia and hyperhomocysteinemia. Physiological Research. 2005;54(1):87-95. Date of Publication: 2005 2005;(1):87–95. [pmid: 15717846].
Raitakari OT, McCredie RJ, Witting P, et al. Coenzyme Q improves LDL resistance to ex vivo oxidation but does not enhance endothelial function in hypercholesterolemic young adults. Free Radical Biology and Medicine. 2000;28(7):1100-1105. Date of Publication: Apr 2000 2000;(7):1100–5. [pmid: 10832071].
Ramos AC, Elias PR, Barrucand L, et al. The protective effect of carnitine in human diphtheric myocarditis. Pediatr Res. Sep. 1984;18(9):815-9. [pmid: 6483504].
Rani PU, Naidu MUR. Clinical efficacy and safety evaluation of eazmov plus in rheumatoid arthritis. Phytomedica. 2006;7:1-7.
Rapola JM. Effects of alpha tocopherol and beta carotene supplements on symptoms, progression, and prognosis of angina pectoris. Heart. 1998;79(5):454-8. [pmid: 9659191].
Dalgård C, Christiansen L, Jonung T, et al. No influence of increased intake of orange and blackcurrant juices and dietary amounts of vitamin E on paraoxonase-1 activity in patients with peripheral arterial disease. Eur J Nutr. Sep. 2007;46(6):1f40-63. [pmid: 17096078].
Reddy KJ, Singh M, Batsell RR, et al. Lipoprotein-associated phospholipase A2 mass is significantly reduced in dyslipidemic patients treated with lifestyle modification and combination lipid-modifying drug therapy. Prev Cardiol. 2010;13(3):130-4. [pmid: 20626668].
Regmi MC, Aggrawal A, Pradhan T, et al. Loading dose versus standard regimen of magnesium sulphate in eclampsia--a randomized trial. Nepal Med Coll J. Dec. 2010;12(4):244-7. [pmid: 21744767].
Rillaerts E, Van CK, Vandewoude MF, et al. Blood viscosity parameters in coronary heart disease: effect of fish oil supplementation. Acta Clin Belg. 1989;44(1):17-23. [pmid: 2763779].
Rizos I. Three-year survival of patients with heart failure caused by dilated cardiomyopathy and L-carnitine administration. Am Heart J. Feb. 2000;139(2 Pt 3):S120-123. [pmid: 10650325].
Gürlek A, Tutar E, Akçil E, et al. The effects of L-carnitine treatment on left ventricular function and erythrocyte superoxide dismutase activity in patients with ischemic cardiomyopathy. Eur J Heart Fail. Jun. 2000;2(2):189-93. [pmid: 10856733].
Robinson I, de Serna DG, Gutierrez A, et al. Vitamin E in humans: an explanation of clinical trial failure. [Review] [45 refs]. Endocr Pract. Sep. 2006;12(5):576-82. [pmid: 17002935].
Rodrigues CA, Morelli VM, DA, Silveira RC, et al. Homocysteine reduction by B-vitamin supplementation increases t-PA and PAI-1 levels in patients with venous thromboembolism. J Thromb Haemost. Jan. 2007;5(1):195-8. [pmid: 17059414].
Rosenfeldt FL, Haas SJ, Krum H, et al. Coenzyme Q10 in the treatment of hypertension: a meta-analysis of the clinical trials. J Hum Hypertens. Apr. 2007;21(4):297-306. [pmid: 17287847].
Rotblatt M. Coenzyme Q_10_ for migraine prophylaxis: The first RCT. Focus on Alternative and Complementary Therapies. 2005;10(3):194-5.
Rowe BH, Bretzlaff JA, Bourdon C, et al. Intravenous magnesium sulfate treatment for acute asthma in the emergency department: a systematic review of the literature. Ann Emerg Med. Sep. 2000;36(3):181-90. [pmid: 10969218].
Rowe MJ, Oliver MF. Proceedings: Effect of nicotinic acid analogue on plasma free fatty acids and ventricular arrhythmias after myocardial infarction. Br Heart J. Oct. 1974;36(10):1037. [pmid: 4611459].
Royer DJ, George JN, Terrell DR. Thrombocytopenia as an adverse effect of complementary and alternative medicines, herbal remedies, nutritional supplements, foods, and beverages. European Journal of Haematology. 2010;84(5):421-429. Date of Publication: May 2010 2010;(5):421–9. [pmid: 20525061].
Rudnicki M, Frölich A, Rasmussen WF, et al. The effect of magnesium on maternal blood pressure in pregnancy-induced hypertension. A randomized double-blind placebo-controlled trial. Acta Obstetricia et Gynecologica Scandinavica. 1991;70(6):445-50. [pmid: 1763608].
Russo A, Stevens JE, Wilson T, et al. Guar attenuates fall in postprandial blood pressure and slows gastric emptying of oral glucose in type 2 diabetes. Dig Dis Sci. Jul. 2003;48(7):1221-9. [pmid: 12870776].
Ryu J, Lerner J, Sullivan JM. Unresponsiveness of forearm hemodynamics to omega-3 polyunsaturated fatty acids and aspirin. Prostaglandins. Mar. 1990;39(3):339-47. [pmid: 2339203].
Sagar SM. Should patients take or avoid antioxidant supplements during anticancer therapy? An evidence-based review. Current Oncology. 2005;12(2):44-54.
Saify ZS, Hassan S, Arif M, et al. A comparative study of omega-3-fatty acids obtained from marine fish and bezafibrate alone and in combination as hypolipidemic agents. Pakistan Journal of Pharmaceutical Sciences. Jan. 2000;13(1):1-11. [pmid: 16414833].
Saku K, Hirata K, Zhang B, et al. Effects of Chinese herbal drugs on serum lipids, lipoproteins and apolipoproteins in mild to moderate essential hypertensive patients. J Hum Hypertens. Oct. 1992;6(5):393-5. [pmid: 1464897].
Salachas A, Papadopoulos C, Sakadamis G, et al. Effects of a low-dose fish oil concentrate on angina, exercise tolerance time, serum triglycerides, and platelet function. Angiology. Dec. 1994;45(12):1023-31. [pmid: 7985829].
Sanjuliani AF, de Abreu Fagundes VG, Francischetti EA. Effects of magnesium on blood pressure and intracellular ion levels of Brazilian hypertensive patients. Int J Cardiol. Oct. 11. 1996;56(2):177-83. [pmid: 8894790].
César LA, Gowdak LH, Mansur AP. The metabolic treatment of patients with coronary artery disease: effects on quality of life and effort angina. [Review] [62 refs]. Curr Pharm Des. 2009;15(8):841-9. [pmid: 19275648].
Sarris J, Kavanagh DJ. Kava and St. John's wort: Current evidence for use in mood and anxiety disorders. J Altern Complement Med. 2009;15(8):827-36. [pmid: 19614563].
Satitvipawee P, Rawdaree P, Indrabhakti S, et al. No effect of garlic extract supplement on serum lipid levels in hypercholesterolemic subjects. J Med Assoc Thai. Aug. 2003;86(8):750-7. [pmid: 12948274].
Satoh N, Shimatsu A, Kotani K, et al. Highly purified eicosapentaenoic acid reduces cardio-ankle vascular index in association with decreased serum amyloid A-LDL in metabolic syndrome. Hypertens Res. Nov. 2009;32(11):1004-8. [pmid: 19763135].
Schmidt EB, Kristensen SD, S⊘rensen PJ, et al. Antithrombin III and protein C in stable angina pectoris--influence of dietary supplementation with polyunsaturated fatty acids. Scand J Clin Lab Invest. Sep. 1988;48(5):469-73. [pmid: 3060987].
Schmidt U, Albrecht M, Schmidt S. Effects of an herbal crataegus-camphor combination on the symptoms of cardiovascular diseases. [German]. Arzneimittelforschung. Jul. 2000;50(7):613-9. [pmid: 10965417].
Schmitz PG, McCloud LK, Reikes ST, et al. Prophylaxis of hemodialysis graft thrombosis with fish oil: double-blind, randomized, prospective trial. J Am Soc Nephrol. Jan. 2002;13(1):184-90. [pmid: 11752036].
Schnitzler R, Fritz KW. A comparative clinical investigation of the diuretic furosemide. [German]. Arzneimittelforschung. May. 1966;16(5):630-4. [pmid: 6014430].
Schreiber FK. Peripheral blood circulation disorders and nicotinic acid. [German]. Med Welt. Jan. 21. 1967;3:176-9. [pmid: 6076050].
Schweikart J, Reimann J, Schö, et al. Investigation of niacin on parameters of metabolism in a physiologic dose: randomized, double-blind clinical trial with three different dosages. Int J Food Sci Nutr. Suppl 5. 2009;60:192-202. [pmid: 19521894].
Scripnikov A, Khomenko A, Napryeyenko O, et al. Effects of Ginkgo biloba extract EGb 761 on neuropsychiatric symptoms of dementia: findings from a randomised controlled trial. Wien Med Wochenschr. 2007;157(13–14):295-300. [pmid: 17704975].
Serebruany VL, Ordonez JV, Herzog WR, et al. Dietary coenzyme Q10 supplementation alters platelet size and inhibits human vitronect 600 in (CD51/CD61) receptor expression. J Cardiovasc Pharmacol. Jan. 1997;29(1):16-22. [pmid: 9007665].
Shafiq N, Singh M, Kaur S, et al. Dietary treatment for familial hypercholesterolaemia. Cochrane database of systematic reviews (Online). 2010;(1):CD001918. [pmid: 20091526].
Sharma VK, Steinberg EN, Vasudeva R, et al. Randomized, controlled study of pretreatment with magnesium citrate on the quality of colonoscopy preparation with polyethylene glycol electrolyte lavage solution. Gastrointest Endosc. Dec. 1997;46(6):541-3. [pmid: 9434223].
Shekelle PG, Hardy ML, Morton SC, et al. Efficacy and safety of ephedra and ephedrine for weight loss and athletic performance: a meta-analysis. J Am Med Assoc. Mar. 26. 2003;289(12):1537-45. [pmid: 12672771].
Shekelle PG, Morton SC, Jungvig LK, et al. Effect of supplemental vitamin E for the prevention and treatment of cardiovascular disease. J Gen Intern Med. Apr. 2004;19(4):380-9. [pmid: 15061748].
Shenoy KT, Lena KB, Sali N, et al. Rationale and design for the CARDIOVIT Study (Cardiovit, Atherosclerotic vascular disease and hypeRhomocysteinemia: an epiDemiological study in Indians, additionally evaluating the effect of Oral VITamin supplementation). Curr Med Res Opin. Apr. 2006;22(4):641-8. [pmid: 16684424].
Shepherd J, Jones J, Frampton GK, et al. Intravenous magnesium sulphate and sotalol for prevention of atrial fibrillation after coronary artery bypass surgery: a systematic review and economic evaluation. [Review] [66 refs]. Health Technol Assess. Jun. 20. 95 B.C.;12(28):iii-iiv. [pmid: 18547499].
Shimizu H, Ohtani K, Tanaka Y, et al. Long-term effect of eicosapentaenoic acid ethyl (EPA-E) on albuminuria of non-insulin dependent diabetic patients. Diabetes Res Clin Pract. Apr. 1995;28(1):35-40. [pmid: 7587910].
Shoji T, Shinohara K, Kimoto E, et al. Lower risk for cardiovascular mortality in oral 1alpha-hydroxy vitamin D3 users in a haemodialysis population. Nephrol Dial Transplant. Jan. 2004;19(1):179-84. [pmid: 14671054].
Silagy C, Neil A. Garlic as a lipid lowering agent - A meta-analysis. J R Coll Physicians Lond. 1994;28(1):39-45. [pmid: 8169881].
Silverman DI, Ware JA, Sacks FM, et al. Comparison of the absorption and effect on platelet function of a single dose of n-3 fatty acids given as fish or fish oil. Am J Clin Nutr. May. 1991;53(5):1165-70. [pmid: 1826984].
Silverman M. Magnesium sulfate in prehospital care. [Review] [28 refs]. Emerg Med Serv. Aug. 2004;33(8):105-7. [pmid: 15368985].
Simopoulos AP. Omega-3 fatty acids in the prevention-management of cardiovascular disease. [Review] [50 refs]. Can J Physiol Pharmacol. Mar. 1997;75(3):234-9. [pmid: 9164707].
Singh RB, Niaz MA, Ghosh S, et al. Effect on mortality and reinfarction of adding fruits and vegetables to a prudent diet in the indian experiment of infarct survival (IEIS). Journal of the American College of Nutrition. 1993;12(3):255-261. Date of Publication: 1993 1993;(3):255–61. [pmid: 8409079].
Singh RB, Niaz MA, Rastogi SS, et al. Usefulness of antioxidant vitamins in suspected acute myocardial infarction (the Indian experiment of infarct survival-3). Am J Cardiol. Feb. 1. 1996;77(4):232-6. [pmid: 8607399].
Singhal S. Comparison of antioxidant efficacy of vitamin E, vitamin C, vitamin A and fruits in coronary heart disease: a controlled trial. J Assoc Physicians India. 2001;49:327-31. [pmid: 11291971].
Skough K, Krossen C, Heiwe S, et al. Effects of resistance training in combination with coenzyme Q10 supplementation in patients with post-polio: A pilot study. Journal of Rehabilitation Medicine. 2008;40(9):773-775. Date of Publication: October 2008 2008;(9):773–5. [pmid: 18843432].
Skyrme-Jones RA, O’Brien RC, Berry KL, et al. Vitamin E supplementation improves endothelial function in type I diabetes mellitus: a randomized, placebo-controlled study. J Am Coll Cardiol. Jul. 2000;36(1):94-102. [pmid: 10898419].
Sobenin IA, Andrianova IV, Fomchenkov IV, et al. Time-released garlic powder tablets lower systolic and diastolic blood pressure in men with mild and moderate arterial hypertension. Hypertens Res. Jun. 2009;32(6):433-7. [pmid: 19390538].
Soeken KL, Miller SA, Ernst E. Herbal medicines for the treatment of rheumatoid arthritis: A systematic review. Rheumatology (UK). 2003;42(5):652-9.
Sorano GG, Biondi G, Conti M, et al. Controlled vitamin K content diet for improving the management of poorly controlled anticoagulated patients: a clinical practice proposal. Haemostasis. Mar. 1993;23(2):77-82. [pmid: 8365689].
Sotaniemi EA, Haapakoski E, Rautio A. Ginseng therapy in non-insulin-dependent diabetic patients. Diabetes Care. 1995;18(10):1373-5. [pmid: 8721940].
Stampfer MJ, Jakubowski JA, Faigel D, et al. Vitamin E supplementation effect on human platelet function, arachidonic acid metabolism, and plasma prostacyclin levels. Am J Clin Nutr. Apr. 1988;47(4):700-6. [pmid: 3128100].
Steinberg FM, Guthrie NL, Villablanca AC, et al. Soy protein with isoflavones has favorable effects on endothelial function that are independent of lipid and antioxidant effects in healthy postmenopausal women. Am J Clin Nutr. Jul. 2003;78(1):123-30. [pmid: 12816781].
Steiner A, Oertel R, Bättig B, et al. Effect of fish oil on blood pressure and serum lipids in hypertension and hyperlipidaemia. J Hypertens Suppl. May. 1989;7(3):S73-76. [pmid: 2547916].
Steiner M, Lin RS. Changes in platelet function and susceptibility of lipoproteins to oxidation associated with administration of aged garlic extract. J Cardiovasc Pharmacol. Jun. 1998;31(6):904-8. [pmid: 9641475].
Steiner M. Vitamin E, a modifier of platelet function: rationale and use in cardiovascular and cerebrovascular disease. Nutr Rev. Oct. 1999;57(10):306-9. [pmid: 10575906].
Steiner M, Li W. Aged garlic extract, a modulator of cardiovascular risk factors: a dose-finding study on the effects of AGE on platelet functions. J Nutr. Mar. 2001;131(3s):980S-4S. [pmid: 11238801].
Stephens NG, Parsons A, Schofield PM, et al. Randomised controlled trial of vitamin E in patients with coronary disease: Cambridge Heart Antioxidant Study (CHAOS). La 1f40 ncet. Mar. 23. 1996;347(9004):781-6. [pmid: 8622332].
Stepura OB, Martynow AI. Magnesium orotate in severe congestive heart failure (MACH). [Erratum appears in Int J Cardiol. 2009 May 1;134(1):144].[Republished in Int J Cardiol. 2009 Jan 9;131(2):293–5; PMID: 18281113]. Int J Cardiol. May. 1. 2009;134(1):145-7. [pmid: 19367681].
Stirban A, Nandrean S, Götting C, et al. Effects of n-3 fatty acids on macro- and microvascular function in subjects with type 2 diabetes mellitus. Am J Clin Nutr. Mar. 2010;91(3):808-13. [pmid: 20071644].
Stutzer G. Drug therapy of the varicose syndrome using Evilettes. [German]. Z Hautkr. Jul. 15. 1977;52(14):733-5. [pmid: 899108].
Sueta CA, Patterson JH, Adams KF Jr. Antiarrhythmic action of pharmacological administration of magnesium in heart failure: a critical review of new data. [Review] [78 refs]. Magnes Res. Dec. 1995;8(4):389-401. [pmid: 8861138].
Sun T, Zhou WB, Luo XP, et al. Oral L-arginine supplementation in acute myocardial infarction therapy: a meta-analysis of randomized controlled trials. Clin Cardiol. Nov. 2009;32(11):649-52. [pmid: 19938054].
Sun Y, Zhang Y, Zhou C. Clinical observation on effect of yixin yidu decoction in treating acute viral myocarditis. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Nov. 2000;20(11):821-3. [pmid: 11938826].
Sung J, Han KH, Zo JH, et al. Effects of red ginseng upon vascular endothelial function in patients with essential hypertension. Am J Chin Med. 2000;28(2):205-16. [pmid: 10999439].
Suzuki S, Hinokio Y, Ohtomo M, et al. The effects of coenzyme Q10 treatment on maternally inherited diabetes mellitus and deafness, and mitochondrial DNA 3243 (A to G) mutation. Diabe 1f40 tologia. May. 1998;41(5):584-8. [pmid: 9628277].
Svensson M, Christensen JH, S⊘lling J, et al. The effect of n-3 fatty acids on plasma lipids and lipoproteins and blood pressure in patients with CRF. Am J Kidney Dis. Jul. 2004;44(1):77-83. [pmid: 15211441].
Swain R, Kaplan-Machlis B. Magnesium for the next millennium. [Review] [51 refs]. South Med J. Nov. 1999;92(11):1040-7. [pmid: 10586828].
Szczeklik A, Gryglewski RJ, Sladek K, et al. Dihomo-gamma-linolenic acid in patients with atherosclerosis: effects on platelet aggregation, plasma lipids and low-density lipoprotein-induced inhibition of prostacyclin generation. Thromb Haemost. Apr. 30. 1984;51(2):186-8. [pmid: 6377563].
Szczeklik A, Gryglewski RJ, Domagala B, et al. Dietary supplementation with vitamin E in hyperlipoproteinemias: effects on plasma lipid peroxides, antioxidant activity, prostacyclin generation and platelet aggregability. Thromb Haemost. Aug. 30. 1985;54(2):425-30. [pmid: 3909500].
Sze FK, Yeung FF, Wong E, et al. Does Danshen improve disability after acute ischaemic stroke? (DARE structured abstract). Acta Neurol Scand. 2004;111:118-25. [pmid: 15644072].
Sze FK, Yeung FF, Wong E, et al. Does Danshen improve disability after acute ischaemic stroke?. [Review] [27 refs]. Acta Neurol Scand. Feb. 2005;111(2):118-25. [pmid: 15644072].
Taku K, Umegaki K, Sato Y, et al. Soy isoflavones lower serum total and LDL cholesterol in humans: a meta-analysis of 11 randomized controlled trials. [Erratum appears in Am J Clin Nutr. 2007 Sep;86(3):809]. Am J Clin Nutr. Apr. 2007;85(4):1148-56. [pmid: 17413118].
Talati R, Sobieraj DM, Makanji SS, et al. The comparative efficacy of plant sterols and stanols on serum lipids: a systematic review and meta-analysis. [Review] [34 refs]. J Am Diet Assoc. May. 2010;110(5):719-26. [pmid: 20430133].
Tan Y, Liu M, Wu B. Puerarin for acute ischaemic stroke. Cochrane Database Syst Rev. 2008;(1):CD004955. [pmid: 18254067].
Tauchert M, Ploch M, Hubner W-D. Effectiveness of the hawthorn extract LI 132 compared with the ACE inhibitor captopril. Multicentre double-blind study with 132 NYHA stage II heart failure patients. Munch Med Wochenschr. 1994;136(Suppl 1):S27-S33.
Tauchert M. Efficacy and safety of crataegus extract WS 1442 in comparison with placebo in patients with chronic stable New York Heart Association class-III heart failure. Am Heart J. May. 2002;143(5):910-5. [pmid: 12040357].
Taylor DM, Walsham N, Taylor SE, et al. Potential interactions between prescription drugs and complementary and alternative medicines among patients in the emergency department. Pharmacotherapy. May. 2006;26(5):634-40. [pmid: 16637793].
Taziki O, Lessan-Pezeshki M, Akha O, et al. The effect of low dose omega-3 on plasma lipids in hemodialysis patients. Saudi J Kidney Dis Transpl. Nov. 2007;18(4):571-6. [pmid: 17951945].
Teixeira CC, Weinert LS, Barbosa DC, et al. Syzygium cumini (L.) Skeels in the treatment of type 2 diabetes: results of a randomized, double-blind, double-dummy, controlled trial. Diabetes Care. 2004;27(12):3019-20. [pmid: 15562231].
Teo KK, McAlister FA, Montague TJ. Results of randomized clinical trials of magnesium--can a consensus be reached?. [Review] [42 refs]. Coron Artery Dis. May. 1996;7(5):341-7. [pmid: 8866198].
Tepper SJ. Alternative medicine in migraine: Is it ever a good alternative?. Consultant. 2005;45(6):662-6.
Terres W, Beil U, Reimann B, et al. Low-dose fish oil in primary hypertriglyceridemia. A randomized placebo-controlled study. [German]. Z Kardiol. Jan. 1991;80(1):20-4. [pmid: 2035283].
Tesch BJ. Herbs commonly used by women: an evidence-based review. [Review] [184 refs]. Am J Obstet Gynecol. May. 2003;188(5 Suppl):S44-55. [pmid: 12748451].
Thompson L, Spiller RC. Impact of polyunsaturated fatty acids on human colonic bacterial metabolism: an in vitro and in vivo study. Br J Nutr. Nov. 1995;74(5):733-41. [pmid: 8541279].
Tiano L, Belardinelli R, Carnevali P, et al. Effect of coenzyme Q10 administration on endothelial function and extracellular superoxide dismutase in patients with ischaemic heart disease: a double-blind, randomized controlled study. Eur Heart J. Sep. 2007;28(18):2249-55. [pmid: 17644511].
Tomeo AC, Geller M, Watkins TR, et al. Antioxidant effects of tocotrienols in patients with hyperlipidemia and carotid stenosis. Lipids. Dec. 1995;30(12):1179-83. [pmid: 8614310].
Tremoli E, Maderna P, Marangoni F, et al. Prolonged inhibition of platelet aggregation after n-3 fatty acid ethyl ester ingestion by healthy volunteers. Am J Clin Nutr. Mar. 1995;61(3):607-13. [pmid: 7872228].
Ude M, Hengstler S, Schulz M, et al. Mineral nutrients and trace elements - a case for consultation. [German]. Pharmazie in Unserer Zeit. 2009;38(3):268-276. Date of Publication: May 2009 2009;(3):268–76. [pmid: 19396919].
Ulbricht C, Basch E, Weissner W, et al. An evidence-based systematic review of herb and supplement interactions by the Natural Standard Research Collaboration. [Review] [83 refs]. Expert Opin Drug Saf. Sep. 2006;5(5):719-28. [pmid: 16907661].
Ulbricht C, Weissner W, Hashmi S, et al. Essiac: systematic review by the natural standard research collaboration. J Soc Integr Oncol. 2009;7(2):73-80. [pmid: 19476742].
Ulbricht C, Weissner W, Basch E, et al. Maitake mushroom (Grifola frondosa): Systematic review by the natural standard research collaboration. J Soc Integr Oncol. 2009;7(2):66-72. [pmid: 19476741].
Ulbricht C, Isaac R, Milkin T, et al. An evidence-based systematic review of stevia by the Natural Standard Research Collaboration. [Review] [70 refs]. Cardiovasc Hematol Agents Med Chem. Apr. 2010;8(2):113-27. [pmid: 20370653].
Ushiroyama T, Ikeda A, Ueki M. Effect of continuous combined therapy with vitamin K(2) and vitamin D(3) on bone mineral density and coagulofibrinolysis function in postmenopausal women. Maturitas. Mar. 25. 2002;41(3):211-21. [pmid: 11886767].
van Doorn MB, Espirito Santo SM, Meijer P, et al. Effect of garlic powder on C-reactive protein and plasma lipids in overweight and smoking subjects. Am J Clin Nutr. Dec. 2006;84(6):1324-9. [pmid: 17158412].
van Mierlo LA, Arends LR, Streppel MT, et al. Blood pressure response to calcium supplementation: a meta-analysis of randomized controlled trials. J Hum Hypertens. Aug. 2006;20(8):571-80. [pmid: 16673011].
van Norden AG, van den Bergh WM, Rinkel GJ. Dose evaluation for long-term magnesium treatment in aneurysmal subarachnoid haemorrhage. J Clin Pharm Ther. Oct. 2005;30(5):439-42. [pmid: 16164489].
van EA, Henny FC, Kooistra MP, et al. Amelioration of cardiac function by L-carnitine administration in patients on haemodialysis. Contrib Nephrol. 1992;98:28-35. [pmid: 1493731].
Verma SK, Singh J, Khamesra R, et al. Effect of ginger on platelet aggregation in man. Indian J Med Res. Oct. 1993;98:240-2. [pmid: 8119760].
Vernaglione L, Cristofano C, Chimienti S. Omega-3 polyunsaturated fatty acids and proxies of cardiovascular disease in hemodialysis: A prospective cohort study. Journal of Nephrology. 2008;21(1):99-105. Date of Publication: Jan 2008 2008;(1):99–105. [pmid: 18264942].
Véricel E, Calzada C, Chapuy P, et al. The influence of low intake of n-3 fatty acids on platelets in elderly people. Atherosclerosis. 1999;147(1):187-92. [pmid: 10525140].
Villa B, Calabresi L, Chiesa G, et al. Omega-3 fatty acid ethyl esters increase heart rate variability in patients with coronary disease. Pharmacol Res. Jun. 2002;45(6):475. [pmid: 12162948].
Villeneuve EJ, Zed PJ. Nebulized magnesium sulfate in the management of acute exacerbations of asthma (DARE structured abstract). Ann Pharmacother. 2006;40:1118-24. [pmid: 16735656].
Virtamo J. Effect of vitamin E and beta carotene on the incidence of primary nonfatal myocardial infarction and fatal coronary heart disease. Arch Intern Med. 1998;158(6):668-75. [pmid: 9521232].
Vitetta L, Sali A, Reavley NJ. Is coenzyme Q10 helpful for patients with idiopathic cardiomyopathy?. Med J Aust. Oct. 15. 2001;175(8):447-8. [pmid: 11700847].
Vitseva O, Varghese S, Chakrabarti S, et al. Grape seed and skin extracts inhibit platelet function and release of reactive oxygen intermediates. J Cardiovasc Pharmacol. Oct. 2005;46(4):445-51. [pmid: 16160595].
Vivekananthan DP, Penn MS, Sapp SK, et al. Use of antioxidant vitamins for the prevention of cardiovascular disease: meta-analysis of randomised trials. Lancet. Jun. 14. 2003;361(9374):2017-23. [pmid: 12814711].
Vogt A, Kassner U, Hostalek U, et al. Safety and tolerability of nicotinic acid. Results of the multicenter, open, prospective NAUTILUS study. [German]. MMW Fortschr Med. May. 4. 2006;148(18):41. [pmid: 16736688].
Vuksan V, Sung MK, Sievenpiper JL, et al. Korean red ginseng (Panax ginseng) improves glucose and insulin regulation in well-controlled, type 2 diabetes: results of a randomized, double-blind, placebo-controlled study of efficacy and safety. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2008;18(1):46-56.
Walker AF, Marakis G, Morris AP, et al. Promising hypotensive effect of hawthorn extract: a randomized double-blind pilot study of mild, essential hypertension. PHYTOTHER RES. Feb. 2002;16(1):48-54. [pmid: 11807965].
Walker AF, Marakis G, Simpson E, et al. Hypotensive effects of hawthorn for patients with diabetes taking prescription drugs: a randomised controlled trial. Br J Gen Pract. Jun. 2006;56(527):437-43. [pmid: 16762125].
Wang C, Li Y, Zhu K, et al. Effects of supplementation with multivitamin and mineral on blood pressure and C-reactive protein in obese Chinese women with increased cardiovascular disease risk. Asia Pac J Clin Nutr. 2009;18(1):121-30. [pmid: 19329405].
Wang J, Lu Z, Chi J, et al. Multicenter clinical trial of the serum lipid-lowering effects of a Monascus purpureus (red yeast) rice preparation from traditional Chinese medicine. Current Therapeutic Research Clinical and Experimental. 1997;58(12):964-78.
Wang S, Ma AQ, Song SW, et al. Fish oil supplementation improves large arterial elasticity in overweight hypertensive patients. Eur J Clin Nutr. Dec. 2008;62(12):1426-31. [pmid: 17805229].
Wang Z-J, Li H-X, Wang J-H, et al. Effect of Shugan Jianpi granule on gut mucosal serotonin-positive cells in patients with irritable bowel syndrome of stagnated Gan-qi attacking Pi syndrome type. Chin J Integr Med. 2008;14(3):185-9. [pmid: 18853113].
Watts GF, Playford DA, Croft KD, et al. Coenzyme Q_10_ improves endothelial dysfunction of the brachial artery in Type II diabetes mellitus. Diabe 1f40 tologia. 2002;45(3):420-6.
Weant KA, Smith KM. The role of coenzyme Q10 in heart failure. [Review] [18 refs]. Ann Pharmacother. Sep. 2005;39(9):1522-6. [pmid: 16046484].
Weber C, Jakobsen TS, Mortensen SA, et al. Effect of dietary coenzyme Q_10_as an antioxidant in human plasma. Mol Aspects Med. 1994;15(SUPPL 1):S97-102. [pmid: 7752850].
Wei ZH, Wang H, Chen XY, et al. Time- and dose-dependent effect of psyllium on serum lipids in mild-to-moderate hypercholesterolemia: a meta-analysis of controlled clinical trials. Eur J Clin Nutr. Jul. 2009;63(7):821-7. [pmid: 18985059].
Weikl A, Assmus KD, Neukum-Schmidt A, et al. Crataegus Special Extract WS 1442. Assessment of objective effectiveness in patients with heart failure (NYHA II). [German]. Fortschr Med Orig. Aug. 30. 1996;114(24):291-6. [pmid: 8974970].
Weiss N, Ide N, Abahji T, et al. Aged garlic extract improves homocysteine-induced endothelial dysfunction in macro- and microcirculation. J Nutr. Mar. 2006;136(3 Suppl):750S-4S. [pmid: 16484556].
Whalley LJ, Fox HC, Lemmon HA, et al. Dietary supplement use in old age: Associations with childhood IQ, current cognition and health. International Journal of Geriatric Psychiatry. 2003;18(9):769-776. Date of Publication: 01 Sep 2003 2003;9(769):76. [pmid: 12949843].
Whang R, Hampton EM, Whang DD. Magnesium homeostasis and clinical disorders of magnesium deficiency. [Review] [66 refs]. Ann Pharmacother. Feb. 1994;28(2):220-6. [pmid: 8173141].
Whittaker JA, Al-Ismail SA. Effect of digoxin and vitamin E in preventing cardiac damage caused by doxorubicin in acute myeloid leukaemia. Br Med J (Clin Res Ed). Jan. 28. 1984;288(6413):283-4. [pmid: 6419896].
Whitten DL, Myers SP, Hawrelak JA, et al. The effect of St John’s wort extracts on CYP3A: A systematic review of prospective clinical trials. Br J Clin Pharmacol. 2006;62(5):512-26. [pmid: 17010103].
Widman L, Wester PO, Stegmayr BK, et al. The dose-dependent reduction in blood pressure through administration of magnesium. A double blind placebo controlled cross-over study. Am J Hypertens. Jan. 1993;6(1):41-5. [pmid: 8427660].
Wilson ML, Murphy PA. Herbal and dietary therapies for primary and secondary dysmenorrhoea. Cochrane database of systematic reviews (Online). 2001;(3):CD002124. [pmid: 11687013].
Wirth JH, Hudgins JC, Paice JA. Use of herbal therapies to relieve pain: a review of efficacy and adverse effects. [Review] [83 refs]. Pain Manag Nurs. Dec. 2005;6(4):145-67. [pmid: 16337563].
Witham MD, Nadir MA, Struthers AD. Effect of vitamin D on blood pressure: a systematic review and meta-analysis. [Review] [30 refs]. J Hypertens. Oct. 2009;27(10):1948-54. [pmid: 19587609].
Witham MD, Crighton LJ, Gillespie ND, et al. The effects of vitamin D supplementation on physical function and quality of life in older patients with heart failure: a randomized controlled trial. Circ. Mar. 2010;3(2):195-201. [pmid: 20103775].
Witteman JC, Grobbee DE, Derkx FH, et al. Reduction of blood pressure with oral magnesium supplementation in women with mild to moderate hypertension. Am J Clin Nutr. Jul. 1994;60(1):129-35. [pmid: 8017327].
Wiygul JB, Evans BR, Peterson BL, et al. Supplement use among men with prostate cancer. Urology. 2005;66(1):161-166. Date of Publication: Jul 2005 2005;(1):161–6. [pmid: 15992901].
Wohl DA, Tien HC, Busby M, et al. Randomized study of the safety and efficacy of fish oil (omega-3 fatty acid) supplementation with dietary and exercise counseling for the treatment of antiretroviral therapy-associated hypertriglyceridemia. Clin Infect Dis. Nov. 15. 2005;41(10):1498-504. [pmid: 16231263].
Wojcikowski K, Myers S, Brooks L. Effects of garlic oil on platelet aggregation: a double-blind placebo-controlled crossover study. Platelets. 2007;18(1):29-34. [pmid: 17365851].
Wojenski CM, Silver MJ, Walker J. Eicosapentaenoic acid ethyl ester as an antithrombotic agent: comparison to an extract of fish oil. Biochim Biophys Acta. Jan. 4. 1991;1081(1):33-8. [pmid: 1991153].
Wolzt M, Ugurluoglu A, Schmetterer L, et al. Exogenous L-arginine does not affect angiotensin II-induced renal vasoconstriction in man. Br J Clin Pharmacol. Jan. 1998;45(1):71-5. [pmid: 9489597].
Wong GK, Poon WS. Magnsium and vasospasm. J Neurosurg. 2007;106(5):938-9. [pmid: 17542548].
Wu B, Liu M, Liu H, et al. Meta-analysis of traditional Chinese patent medicine for ischemic stroke. Stroke. Jun. 2007;38(6):1973-9. [pmid: 17463317].
Wu G, Tian H, Han K, et al. Potassium magnesium supplementation for four weeks improves small distal artery compliance and reduces blood pressure in patients with essential hypertension. Clin Exp Hypertens. Jul. 2006;28(5):489-97. [pmid: 16820345].
Wu SH, Ho SC, Zhong L. Effects of vitamin D supplementation on blood pressure. South Med J. Aug. 2010;103(8):729-37. [pmid: 20622727].
Xu G, Zhao W, Zhou Z, et al. Danshen extracts decrease blood C reactive protein and prevent ischemic stroke recurrence: a controlled pilot study. PHYTOTHER RES. Dec. 2009;23(12):1721-5. [pmid: 19449344].
Yasui-Furukori N, Furukori H, Kaneda A, et al. The Effects of Ginkgo biloba Extracts on the Pharmacokinetics and Pharmacodynamics of Donepezil. Journal of Clinical Pharmacology. 2004;44(5):538-542. Date of Publication: May 2004 2004;(5):538–42. [pmid: 15102875].
Yates KM, O’Connor A, Horsley CA. “Herbal Ecstasy”: a case series of adverse reactions. N Z Med J. Jul. 28. 2000;113(1114):315-7. [pmid: 10972312].
Ye H, Du J, Shen D, et al. Effect of shexiang baoxin pill on the function of vascular endothelium in patients with diabetes mellitus type 2 complicated with angina pectoris. [Chinese]. Zhongguo Zhong Xi Yi Jie He Za Zhi. Dec. 2004;24(12):1077-9. [pmid: 15658648].
Ye P, Wu C, Sheng L, et al. Effect of xuezhikang on alpha1- and beta2-microglobulin in patients with essential hypertension. J Hum Hypertens. 2009;23(1):72-4. [pmid: 18668126].
Ye Z, Song H. Antioxidant vitamins intake and the risk of coronary heart disease: meta-analysis of cohort studies. Eur J Cardiovasc Prev Rehabil. Feb. 2008;15(1):26-34. [pmid: 18277182].
Yeh GY, Eisenberg DM, Kaptchuk TJ, et al. Systematic review of herbs and dietary supplements for glycemic control in diabetes. Diabetes Care. 2003;26(4):1277-1294. Date of Publication: 01 Apr 2003 2003;(4):1277–94. [pmid: 12663610].
Yuan Y, Zeng X, Luo Y, et al. Chuanxiong-type preparations for acute ischemic stroke. Cochrane Database Syst Rev. 2008;(4):CD005569. [pmid: 18843695].
Yuen AWC, Sander JW, Fluegel D, et al. Omega-3 fatty acid supplementation in patients with chronic epilepsy: A randomized trial. Epilepsy and Behavior. 2005;7(2):253-258. Date of Publication: Sep 2005 2005;(2):253–8. [pmid: 16006194].
Yvan-Charvet L, Kling J, Pagler T, et al. Cholesterol efflux potential and antiinflammatory properties of high-density lipoprotein after treatment with niacin or anacetrapib. Arterioscler Thromb Vasc Biol. Jul. 2010;30(7):1430-8. [pmid: 20448206].
Yzebe D, Lievre M. Fish oils in the care of coronary heart disease patients: a meta-analysis of randomized controlled trials (DARE structured abstract). Fundam Clin Pharmacol. 2004;18:581-92. [pmid: 15482380].
Zanolla L. Observational series of patients treated either with ACE inhibitors and diuretics or with a homeopathic Crataegus preparation. Eur J Heart Fail. Jun. 2004;6(4):509-8. [pmid: 15182778].
Zehender M, Meinertz T, Faber T, et al. Antiarrhythmic effects of increasing the daily intake of magnesium and potassium in patients with frequent ventricular arrhythmias. Magnesium in Cardiac Arrh 1f40 ythmias (MAGICA) Investigators. J Am Coll Cardiol. Apr. 1997;29(5):1028-34. [pmid: 9120155].
Zhang JH, Shang HC, Gao XM, et al. Compound Salvia droplet pill, a traditional Chinese medicine, for the treatment of unstable angina pectoris: a systematic review. Med Sci Monit. Jan. 2008;14(1):RA1-7. [pmid: 18160949].
Zhang ZF, Kurtz RC, Yu GP, et al. Adenocarcinomas of the esophagus and gastric cardia: the role of diet. Nutr Cancer. 1997;27(3):298-309. [pmid: 9101561].
Zhou SF, Zhou ZW, Li CG, et al. Identification of drugs that interact with herbs in drug development. [Review] [111 refs]. Drug Discov Today. Aug. 2007;12(15–16):664-73. [pmid: 17706549].
Zhu FS, Liu S, Chen XM, et al. Effects of n-3 polyunsaturated fatty acids from seal oils on nonalcoholic fatty liver disease associated with hyperlipidemia. World J Gastroenterol. Nov. 7. 2008;14(41):6395-400. [pmid: 19009658].
Zhu H-L, Zhang S-H, Xia Q. Effect of combination of compound preparation between gingko extract and dipyridamole and methycobal on the treatment of diabetic peripheral neuropathy. Chinese Journal of Clinical Rehabilitation. 2006;10(27):158-60.
Zhuo Q, Yang X, Wu T, et al. Tongxinluo capsule for acute stroke. Cochrane Database Syst Rev. 2008;(4):CD004584. [pmid: 18843664].

## Not Relevant Study Design

Eligiblity criteria: Systematic review; or experimental/observational comparative study (RCT, non-RCT, cohort, case-control, cross-sectional) with independent (concurrent or historical) control group including at least 5 participants

Letter: Effects of vitamin E: good and bad. N Engl J Med. Nov. 1. 1973;289(18):979-80. [pmid: 4200602].
Vitamin K, vitamin E and the coumarin drugs. Nutr Rev. Jun. 1982;40(6):180-2. [pmid: 7121898].
Systematic overview of controlled trials (meta-analysis) helps clarify treatment effects. Drug Ther Bull. Mar. 30. 1992;30(7):25-7. [pmid: 1534294].
Nutritional supplement as energy support for the heart? Coenzyme Q_10_ trial for heart surgery. [German]. Fortschr Med Orig. 1993;111(18):53.
The HOPE. (Heart Outcomes Prevention Evaluation) Study: the design of a large, simple randomized trial of an angiotensin-converting enzyme inhibitor (ramipril) and vitamin E in patients at high risk of cardiovascular events. The HOPE study investigators. Can J Cardiol. Feb. 1996;12(2):127-37. [pmid: 8605634].
ASHP Therapeutic Position Statement on the safe use of niacin in the management of dyslipidemias. American Society of Health-System Pharmacists. Am J Health-Syst Pharm. Dec. 15. 1997;54(24):2815-9. [pmid: 9428952].
Ginkgo biloba for dementia. Med Lett Drugs Ther. Jun. 1998;40(1029):63-4. [pmid: 9653424].
Study of heart failure. Is phytotherapy effective?. [German]. MMW Fortschr Med. Jun. 21. 2001;143(25):59. [pmid: 11469004].
Garlic and your health: the current evidence. [Review] [0 refs]. Harv Mens Health Watch. Sep. 2002;7(2):4-6. [pmid: 12356552].
Aspects of herbal medicines regulation in Europe and the United States. Pharmaceutical Journal. 2002;269(7216):403.
Cardioprotective and anti-arrhythmia omega 3 fatty acids. Protection from sudden cardiac death. [German]. MMW Fortschr Med. Sep. 12. 2002;144(37):54. [pmid: 12380341].
Niacin aids cholesterol control. But choose “extended release” to minimize “flushing” risk. Heart Advis. Jul. 2003;6(7):3. [pmid: 12921040].
FSA issues high-dose vitamins warning. Pharmaceutical Journal. 2003;270(7249):671. Date of Publication: 17 May 2003 2003;(7249):671.
Even in advanced heart failure, hawthorn improves physical capacity. [German]. MMW Fortschr Med. Jan. 16. 2003;145(1–2):5. [pmid: 14699822].
Vitamins for all. South African Journal of Clinical Nutrition. 2003;16(1):2.
Summaries for patients. Ginseng reduces the effect of warfarin in a study of healthy volunteers. Ann Intern Med. Jul. 6. 2004;141(1):I58. [pmid: 15238393].
Supplements have few serious interactions. Pharmaceutical Journal. 2004;272(7293):408. Date of Publication: 03 Apr 2004 2004;(7293):408.
Highly concentrated omega-3-fatty acids. A new means in the secondary prevention. [German]. MMW Fortschr Med. Oct. 27. 2005;147(43):60-1. [pmid: 16302426].
Fish oil and statins have a synergistic action. [German]. MMW Fortschr Med. Dec. 15. 2005;147(51–52):16. [pmid: 16402695].
Fish oil supplements. The Medical letter on drugs and therapeutics. 2006;48(1239):59-60. Date of Publication: 17 Jul 2006 2006;(1239):59–60. [pmid: 16841020].
Does CoQ10 reduce muscle pain caused by taking statins?. Mayo Clin Womens Healthsource. Jan. 2006;10(1):10. [pmid: 16404330].
How well do supplements work? Check this source. Heart advisor/the Cleveland Clinic. 2006;9(12):5. Date of Publication: Dec 2006 2006;(12):5.
Coenzyme Q10. Is it worth the expense?. Mayo Clinic health letter (English ed ). 24(11):6. 2006 Date of Publication: Nov 2006 2006;(English ed.):6.
Discussion. Journal of Vascular Surgery. 2007;45(3):559-560. Date of Publication: Mar 2007 2007;(3):559–60.
Summaries for patients. Is vitamin K helpful for people who have taken too much warfarin?. [Original report in Ann Intern Med. 2009 Mar 3;150(5):293–300; PMID: 19258557]. Ann Intern Med. Mar. 3. 2009;150(5):125. [pmid: 19047022].
Crataegus oxyacantha (Hawthorn). Monograph. [Review] [27 refs]. Altern Med Rev. Jul. 2010;15(2):164-7. [pmid: 20807002].
Elevating your HDL game. “Good” cholesterol levels can be increased in several ways, but taking niacin is the most effective. Harv Health Lett. Jul. 2010;35(9):6-7. [pmid: 20821856].
Crataegus oxyacantha (Hawthorn). Monograph. [Review] [27 refs]. Altern Med Rev. Jul. 2010;15(2):164-7. [pmid: 20807002].
Aarskog D, Aksnes L, Lehmann V. Low 1,25-dihydroxyvitamin D in heparin-induced osteopenia. La 1f40 ncet. Sep. 20. 1980;2(8195 pt 1):650-1. [pmid: 6107445].
Adachi-Akahane S, Kurachi Y. New era for translational research in cardiac arrhythmias. Circ Res. Jun. 8. 2001;88(11):1095-6. [pmid: 11397771].
Aguilar MI, Hart RG, Kase CS, et al. Treatment of warfarin-associated intracerebral hemorrhage: literature review and expert opinion. [Review] [86 refs][Erratum appears in Mayo Clin Proc. 2007 Mar;82(3):387]. Mayo Clin Proc. Jan. 2007;82(1):82-92. [pmid: 17285789].
Ahmed M, Anderson SD, Schofield RS. Coenzyme q10 and creatine in heart failure: micronutrients, macrobenefit?. Clin Cardiol. Apr. 2011;34(4):196-7. [pmid: 21462213].
Alagona P Jr. Beyond LDL cholesterol: the role of elevated triglycerides and low HDL cholesterol in residual CVD risk remaining after statin therapy. [Review] [37 refs]. Am J Manag Care. Mar. 2009;15(3 Suppl):S65-73. [pmid: 19355805].
Alexander J. Adjunctive therapy for acute myocardial infarction. [Review] [23 refs]. Curr Opin Cardiol. Sep. 1997;12(5):453-8. [pmid: 9352172].
Alpers DH. Garlic and its potential for prevention of colorectal cancer and other conditions. Current Opinion in Gastroenterology. 2009;25(2):116-121. Date of Publication: March 2009 2009;(2):116–21. [pmid: 19528879].
Amagase H, Petesch BL, Matsuura H, et al. Intake of garlic and its bioactive components. [Review] [89 refs]. J Nutr. Mar. 2001;131(3s):955S-62S. [pmid: 11238796].
Andreadou I, Iliodromitis EK, Farmakis D, et al. To prevent, protect and save the ischemic heart: antioxidants revisited. [Review] [149 refs]. Expert Opin Ther Targets. Aug. 2009;13(8):945-56. [pmid: 19534573].
Anthony M, Romero K, Malone DC, et al. Warfarin interactions with substances listed in drug information compendia and in the FDA-approved label for warfarin sodium. Clin Pharmacol Ther. Oct. 2009;86(4):425-9. [pmid: 19587643].
Arnesen H, Seljeflot I. Studies on very long chain marine n-3 fatty acids in patients with atherosclerotic heart disease with special focus on mechanisms, dosage and formulas of supplementation. Cell Mol Biol (Noisy-le-grand). 2010;56(1):18-27. [pmid: 20196966].
Arsenian MA. Magnesium and cardiovascular disease. [Review] [420 refs]. Prog Cardiovasc Dis. Jan. 1993;35(4):271-310. [pmid: 7678179].
Athyros VG, Tziomalos K, Mikhailidis DP, et al. Do we need a statin-nicotinic acid-aspirin mini-polypill to treat combined hyperlipidaemia?. [Review] [104 refs]. Expert Opin Pharmacother. Oct. 2007;8(14):2267-77. [pmid: 17927482].
Erkkilä AT, Booth SL. Vitamin K intake and atherosclerosis. [Review] [29 refs]. Curr Opin Lipidol. Feb. 2008;19(1):39-42. [pmid: 18196985].
Lü JM, Yao Q, et al. Ginseng compounds: an update on their molecular mechanisms and medical applications. [Review] [132 refs]. Curr Vasc Pharmacol. Jul. 2009;7(3):293-302. [pmid: 19601854].
Orö L, Olsson AG, et al. Cholestyramine, clofibrate and nicotinic acid as single or combined treatment of type IIa and IIb hyperlipoproteinaemia. Postgrad Med J. 1975;51(8). suppl-81. [pmid: 215986].
Ballantyne CM. Reducing atherothrombotic events in high-risk patients: recent data on therapy with statins and fatty acids. [Review] [8 refs]. Curr Atheroscler Rep. Jul. 1999;1(1):6-8. [pmid: 11122685].
Barker FM II. Dietary supplementation: Effects on visual performance and occurrence of AMD and cataracts. Current Medical Research and Opinion. 2010;26(8):2011-2023. Date of Publication: August 2010 2010;(8):2011–23. [pmid: 20590393].
Bartle WR, Madorin P. Seaweed, vitamin K, and warfarin. Am J Health-Syst Pharm. Dec. 1. 2001;58(23):2300. [pmid: 11763808].
Basch E, Foppa I, Liebowitz R, et al. Lavender (Lavandula angustifolia Miller). J Herbal Pharmacother. 2004;4(2):63-78.
Bays H. Safety of niacin and simvastatin combination therapy. [Review] [26 refs]. Am J Cardiol. Apr. 17. 2008;101(8A):3B-8B. [pmid: 18243856].
Bays HE, Dujovne CA. Drug interactions of lipid-altering drugs. [Review] [57 refs]. Drug Saf. Nov. 1998;19(5):355-71. [pmid: 9825949].
Becker DJ, Gordon RY. In response. Ann Intern Med. 2010;152(2):135-6. [pmid: 20083842].
Berthold HK, Sudhop T. Garlic preparations for prevention of atherosclerosis. [Review] [29 refs]. Curr Opin Lipidol. Dec. 1998;9(6):565-9. [pmid: 9868592].
Bhatnagar D, Durrington PN. Omega-3 fatty acids: their role in the prevention and treatment of atherosclerosis related risk factors and complications. [Review] [131 refs]. Int J Clin Pract. May. 2003;57(4):305-14. [pmid: 12800463].
Bieri JG, Corash L, Hubbard VS. Medical uses of vitamin E. [Review] [113 refs]. N Engl J Med. May. 5. 1983;308(18):1063-71. [pmid: 6339932].
Bigard AX. Ergogenic aids and endocrine system. [Italian, English]. Medicina dello Sport. 2001;54(3):253-5.
Birjmohun RS, Kastelein JJ, Poldermans D, et al. Safety and tolerability of prolonged-release nicotinic acid in statin-treated patients. Curr Med Res Opin. Jul. 2007;23(7):1707-13. [pmid: 17588301].
Block RC, Duff R, Lawrence P, et al. The effects of EPA, DHA, and aspirin ingestion on plasma lysophospholipids and autotaxin. Prostaglandins Leukot Essent Fatty Acids. Feb. 2010;82(2–3):87-95. [pmid: 20106646].
Blum S, Milman U, Shapira C, et al. Dual therapy with statins and antioxidants is superior to statins alone in decreasing the risk of cardiovascular disease in a subgroup of middle-aged individuals with both diabetes mellitus and the haptoglobin 2-2 genotype. Arterioscler Thromb Vasc Biol. Mar. 2008;28(3):e18-e20. [pmid: 18296583].
Blumberg JB. An update: vitamin E supplementation and heart disease. [Review] [34 refs]. Nutr Clin Care. Mar. 2002;5(2):50-5. [pmid: 12134710].
Boak L, Chin-Dusting JPF. Hypercholesterolemia and endothelium dysfunction: Role of dietary supplementation as vascular protective agents. Current Vascular Pharmacology. 2004;2(1):45-52. Date of Publication: Jan 2004 2004;(1):45–52. [pmid: 15320832].
Bonakdar RA, Guarneri E. Coenzyme Q10. American Family Physician. 2005;72(6):1065-1070. Date of Publication: 15 Sep 2005;(6):1065–70. [pmid: 16190504].
Bone KM. Potential interaction of Ginkgo biloba leaf with antiplatelet or anticoagulant drugs: what is the evidence?. [Review] [53 refs]. Mol Nutr Food Res. Jul. 2008;52(7):764-71. [pmid: 18214851].
Boniel T, Dannon P. The safety of herbal medicines in the psychiatric practice. [Review] [27 refs] [Hebrew]. Harefuah. 2001;140(8):780-3. 805. [pmid: 11547487].
Bonjour JP. Vitamins and alcoholism. V. Riboflavin, VI. Niacin, VII. Pantothenic acid, and VIII. Biotin. [Review] [92 refs]. Int J Vitam Nutr Res. 1980;50(4):425-40. [pmid: 7009467].
Bonnefont-Rousselot D. The Role of Antioxidant Micronutrients in the Prevention of Diabetic Complications. Treatments in Endocrinology. 2004;3(1):41-52. Date of Publication: 2004 2004;(1):41–52. [pmid: 15743112].
Boon H. Systematic review of herb-drug interactions. Focus on Alternative and Complementary Therapies. Jun. 2002;7(2):135-6.
Booth SL. Dietary vitamin K guidance: an effective strategy for stable control of oral anticoagulation?. [Review] [15 refs]. Nutr Rev. Mar. 2010;68(3):178-81. [pmid: 20384848].
Borrelli F, Capasso R, Izzo AA. Garlic (Allium sativum L.): adverse effects and drug interactions in humans. [Review] [124 refs]. Mol Nutr Food Res. Nov. 2007;51(11):1386-97. [pmid: 17918162].
Boucher BJ. Endothelial dysfunctionl has vitamin D a role?. Diabet Med. Jan. 2011;28(1):125-6. [pmid: 21166857].
Bouillon R. Vitamin D as potential baseline therapy for blood pressure control. Am J Hypertens. Aug. 2009;22(8):816. [pmid: 19638953].
Boullata J. Natural health product interactions with medication. Nutrition in Clinical Practice. 2005;20(1):33-51. Date of Publication: Feb 2005 2005;(1):33–51. [pmid: 16207645].
Bresolin N, Bet L, Ferrante C, et al. Immunological and biochemical studies and pilot therapeutic trial with ubidecarenone in Kearns-Sayre patients. Adv Neurol. 1988;48:239-56. [pmid: 3334786].
Bressler R. Herb-drug interactions: Interactions between ginseng and prescription medications. Geriatrics. 2005;60(8):16-7. [pmid: 16092887].
Brockes C, Buchli C, Locher R, et al. Vitamin E prevents extensive lipid peroxidation in patients with hypertension. Br J Biomed Sci. 2003;60(1):5-8. [pmid: 12680623].
Bunout D. Therapeutic potential of vitamin E in heart disease. [Review] [45 refs]. Expert Opin Investig Drugs. Nov. 2000;9(11):2629-35. [pmid: 11060825].
Burke LM, Castell LM, Stear SJ, et al. BJSM reviews: A-Z of nutritional supplements: Dietary supplements, sports nutrition foods and ergogenic aids for health and performance Part 4. British Journal of Sports Medicine. 2009;43(14):1088-1090. Date of Publication: December 2009 2009;(14):1088–90.
Butt MS, Sultan MT, Butt MS, et al. Garlic: nature’s protection against physiological threats. [Review] [169 refs]. Crit Rev Food Sci Nutr. Jun. 2009;49(6):538-51. [pmid: 19484634].
Cahill AG, Macones GA, Odibo AO, et al. Magnesium for seizure prophylaxis in patients with mild preeclampsia. Obstet Gynecol. Sep. 2007;110(3):601-7. [pmid: 17766606].
Cannon RO III. Cardiovascular benefit of cholesterol-lowering therapy: does improved endothelial vasodilator function matter?. Circ Cardiovasc Qual Outcomes. Aug. 22. 2000;102(8):820-2. [pmid: 10952945].
Cassetta JA, Valli G, Giardina EG. Cardiovascular benefits and adverse effects of common herbal therapies. Cardiology Review. 2004;21(7):35-9+40.
Cassileth BR, Deng G. Complementary and Alternative Therapies for Cancer. Oncologist. 2004;9(1):80-89. Date of Publication: 2004 2004;(1):80–9. [pmid: 14755017].
Castaño G, MáS R, Fernández L, et al. A comparison of the effects of D-003 and policosanol (5 and 10 mg/day) in patients with type II hypercholesterolemia: a randomized, double-blinded study. Drugs under experimental and clinical research. 2005;31(Suppl):31-44. [pmid: 16444910].
Chan EJ, Cho L. What can we expect from omega-3 fatty acids?. [Review] [29 refs]. Clevel Clin J Med. Apr. 2009;76(4):245-51. [pmid: 19339640].
Cheng TO. Warning about a medicinal herb. Hosp Pract (Minneap ). Sep. 15. 1999;34(10):23. [pmid: 10901744].
Cheng TO. Herbal interaction with warfarin [1]. Southern Medical Journal. 2005;98(7):748. Date of Publication: Jul 2005 2005;(7):748. [pmid: 16108248].
Chew GT, Watts GF. Coenzyme Q10 and diabetic endotheliopathy: oxidative stress and the ‘recoupling hypothesis’. QJM : monthly journal of the Association of Physicians. 2004;97(8):537-548. Date of Publication: Aug 2004 2004;(8):537–48. [pmid: 15256611].
Chin JPF. Marine oils and cardiovascular reactivity. Prostaglandins Leukotrienes and Essential Fatty Acids. 1994;50(5):211-222. Date of Publication: 1994 1994;(5):211–22.
Chockalingam A, Abbott D, Bass M, et al. Recommendations of the Canadian Consensus Conference on Non-Pharmacological Approaches to the Management of High Blood Pressure. Mar. 21–23, 1989. Halifax, Nova Scotia. [Review] [114 refs][Erratum appears in Can Med Assoc J 1990 Aug 1;143(3):177]. CMAJ. Jun. 15. 1990;142(12):1397-409. [pmid: 2190686].
Collins JW. The treatment of mild to moderate hypertension in patients with diabetes mellitus. [Review] [71 refs]. Nurse Pract. 1991;16(6):28-30. [pmid: 1861800].
Comer GM, Ciulla TA. Pharmacotherapy for diabetic retinopathy. [Review] [190 refs][Erratum appears in Curr Opin Ophthalmol. 2005 Jun;16(3):195]. Curr Opin Ophthalmol. Dec. 2004;15(6):508-18. [pmid: 15523197].
Conover EA. Over-the-counter products: Nonprescription medications, nutraceuticals, and herbal agents. Clinical Obstetrics and Gynecology. 2002;45(1):89-98. Date of Publication: 2002 2002;(1):89–98. [pmid: 11862061].
Cooke JP. Nutriceuticals for cardiovascular health. American Journal of Cardiology. 1998;82(10 A):43S-46S. Date of Publication: 19 Nov 1998 1998;(10 A):43S–6S. [pmid: 9860358].
Covington MB. Omega-3 fatty acids. [Review] [34 refs]. Am Fam Phys. Jul. 1. 2004;70(1):133-40. [pmid: 15259529].
Creutzig A. Is Ginkgo biloba extract EGb 761 clinically effective in intermittent claudication?. [German]. Vasa. 1993;22(2):189-90. [pmid: 8322509].
Crippa G, Sverzellati E, Giorgi-Pierfranceschi M, et al. Magnesium and cardiovascular drugs: interactions and therapeutic role. [Review] [51 refs]. Ann Ital Med Int. Jan. 1999;14(1):40-5. [pmid: 10528423].
Cunningham E. Is red yeast rice safe and effective for lowering serum cholesterol?. J Am Diet Assoc. Feb. 2011;111(2):324. [pmid: 21272710].
Cunningham JJ. Micronutrients as nutriceutical interventions in diabetes mellitus. [Review] [25 refs]. J Am Coll Nutr. Feb. 1998;17(1):7-10. [pmid: 9477383].
Daher EF, Silva J, Queiroz AL, et al. Acute kidney injury due to anabolic steroid and vitamin supplement abuse: report of two cases and a literature review. [Review] [34 refs]. Int Urol Nephrol. 2009;41(3):717-23. [pmid: 19387860].
Das UN. Long-chain polyunsaturated fatty acids interact with nitric oxide, superoxide anion, and transforming growth factor-beta to prevent human essential hypertension. [Review] [103 refs]. Eur J Clin Nutr. Feb. 2004;58(2):195-203. [pmid: 14749737].
Das UN. Beneficial actions of polyunsaturated fatty acids in cardiovascular diseases: But, how and why?. Current Nutrition and Food Science. 2008;4(1):2-31. Date of Publication: Feb 2008 2008;(1):2–31.
Daugherty NE, Smith KM. Dietary supplement and selected food interactions with warfarin. Orthopedics. 2006;29(4):309-314. Date of Publication: Apr 2006 2006;(4):309–14. [pmid: 16628990].
Davidson MH. Niacin: a powerful adjunct to other lipid-lowering drugs in reducing plaque progression and acute coronary events. [Review] [22 refs]. Curr Atheroscler Rep. Sep. 2003;5(5):418-22. [pmid: 12911853].
Davidson MH, Geohas CT. Efficacy of over-the-counter nutritional supplements. Current Atherosclerosis Reports. 2003;5(1):15-21. Date of Publication: Jan 2003 2003;(1):15–21. [pmid: 12562537].
Davis W, Rockway S, Kwasny M. Effect of a combined therapeutic approach of intensive lipid management, omega-3 fatty acid supplementation, and increased serum 25 (OH) vitamin D on coronary calcium scores in asymptomatic adults. Am J Ther. Jul. 2009;16(4):326-32. [pmid: 19092644].
De Smet PAGM. The interference of botanicals and nutraceuticals with the effects of antithrombotic agents: How should the available evidence be weighed?. Thrombosis Research. 2005;117(1–2):19-24. Date of Publication 2005 2005;(1–2):19–24. [pmid: 16239022].
DeDea L. When to take statins; Lovaza versus OTC fish oil supplements. JAAPA : official journal of the American Academy of Physician Assistants. 2011;24(5):23.
Deyama T, Nishibe S, Nakazawa Y. Constituents and pharmacological effects of Eucommia and Siberian ginseng. [Review] [90 refs]. Acta Pharmacol Sin. Dec. 2001;22(12):1057-70. [pmid: 11749801].
Di RG. Ginkgo biloba and the central nervous system. [Review] [16 refs]. Fitoterapia. Aug. Suppl 1. 2000;71:S43-47. [pmid: 10930712].
Dickstein K. Practical guidelines for the use of converting enzyme inhibitors in congestive heart failure. [Review] [13 refs]. Int J Cardiol. Apr. 1987;15(1):1-5. [pmid: 3032812].
Diener HC, Danesch U. Effectiveness of chemical, herbal and dietetic migraine prophylactis. An overview of randomized controlled double-blind studies. [German]. MMW Fortschr Med. Jun. 11. 2009;151(24):42-5. [pmid: 19645201].
Digby JE, Lee JM, Choudhury RP. Nicotinic acid and the prevention of coronary artery disease. [Review] [50 refs]. Curr Opin Lipidol. Aug. 2009;20(4):321-6. [pmid: 19494772].
Digiesi V, Lenuzza M, Digiesi G. Prospects for the use of antioxidant therapy in hypertension. [Review] [76 refs]. Ann Ital Med Int. Apr. 2001;16(2):93-100. [pmid: 11688366].
Donadio V, Bonsi P, Zele I, et al. Myoglobinuria after ingestion of extracts of guarana, Ginkgo biloba and kava. Neurol Sci. Apr. 2000;21(2):124. [pmid: 10938194].
Donaldson JO. Does magnesium sulfate treat eclamptic convulsions?. [Review] [106 refs]. Clin Neuropharmacol. 1986;9(1):37-45. [pmid: 3548953].
Dreikorn K, Berges R, Pientka L, et al. Phytotherapy. Current evidence-based evaluation. [German]. Urologe - Ausgabe A. 2002;41(5):447-451. Date of Publication: 2002 2002;(5):447–51.
Drown DJ. The effects of simvastatin-niacin and antioxidant therapy on HDL. Prog Cardiovasc Nurs. 2002;17(2):102-3. [pmid: 11986546].
Dunning T. Complementary therapies: Considerations for diabetes care. Practical Diabetes International. 2004;21(3):118-125. Date of Publication: Apr 2004 2004;(3):118–25.
Durlach J, Durlach V, Bac P, et al. Magnesium and therapeutics. [Review] [136 refs]. Magnes Res. Dec. 1994;7(3–4):313-28. [pmid: 7786695].
Durlach J, Durlach A, Durlach V. Antioxidant dietary status and genetic cardiovascular risk, or how an adequate intake of a-tocopherol, selenium, taurine, magnesium and various other natural antioxidants may overcome the deleterious metabolic consequences related to the E4–4 type of apolipoprotein E. [Review] [24 refs]. Magnes Res. Jun. 1996;9(2):139-41. [pmid: 8878011].
Dustan HR, Tarazi RC, Bravo EL. Diuretic and diet treatment of hypertension. Arch Intern Med. Jun. 1974;133(6):1007-13. [pmid: 4829750].
Dusting GJ, Triggle C. Are we over oxidized? Oxidative stress, cardiovascular disease, and the future of intervention studies with antioxidants. Vasc Health Risk Manag. 2005;1(2):93-7. [pmid: 17315394].
Duvall WL. Endothelial dysfunction and antioxidants. [Review] [57 refs]. Mt Sinai J Med. Mar. 2005;72(2):71-80. [pmid: 15770336].
Elgart ML. Acanthosis nigricans and nicotinic acid. J Am Acad Dermatol. Dec. 1981;5(6):709-10. [pmid: 7320272].
Elsayed NM. Antioxidant mobilization in response to oxidative stress: A dynamic environmental-nutritional interaction. Nutrition. 2001;17(10):828-34. [pmid: 11684389].
Emel’ianov AV, Goncharova VA, Sinitsina TM. The efficacy of the magnesium sulfate aerosol treatment of bronchial asthma patients. [Russian]. Ter Arkh. 1997;69(3):35-9. [pmid: 9229826].
Engelsen J, Nielsen JD, Winther K. Effect of coenzyme Q10 and Ginkgo biloba on warfarin dosage in stable, long-term warfarin treated outpatients. A randomised, double blind, placebo-crossover trial. Thromb Haemost. Jun. 2002;87(6):1075-6. [pmid: 12083489].
Engler MB. Vascular effects of omega-3 fatty acids: possible therapeutic mechanisms in cardiovascular disease. [Review] [68 refs]. J Cardiovasc Nurs. Apr. 1994;8(3):53-67. [pmid: 8024656].
Eritsland J, Arnesen H, Smith P, et al. Effects of highly concentrated omega-3 polyunsaturated fatty acids and acetylsalicylic acid, alone and combined, on bleeding time and serum lipid profile. J Oslo City Hosp. Aug. 1989;39(8–9):97-101. [pmid: 2809856].
Ernst E. Herbal medicinal products. British Journal of General Practice. 2002;52(478):410. Date of Publication: 2002 2002;(478):410. [pmid: 12014541].
Escudero I, Martínez-González G, Alonso R, et al. Experimental and interventional dietary study in humans on the role of HDL fatty acid composition in PGI2 release and Cox-2 expression by VSMC. Eur J Clin Invest. Sep. 2003;33(9):779-86. [pmid: 12925037].
Evans V. Herbs and the brain: friend or foe? The effects of ginkgo and garlic on warfarin use. [Review] [23 refs]. J Neurosci Nurs. Aug. 2000;32(4):229-32. [pmid: 10994537].
Faisel H, Pittrof R. Vitamin A and causes of maternal mortality: association and biological plausibility. Public Health Nutr. Sep. 2000;3(3):321-7. [pmid: 10979152].
Fang IM, Yang CH, Yang CM, et al. Comparative effects of fatty acids on proinflammatory gene cyclooxygenase 2 and inducible nitric oxide synthase expression in retinal pigment epithelial cells. Mol Nutr Food Res. Jun. 2009;53(6):739-50. [pmid: 19437483].
Fang S, Wu J. Resolution of statin-induced myalgias by correcting vitamin D deficiency. South Med J. May. 2011;104(5):380. [pmid: 21606729].
Farber A, Mcfee RB. Herbal medications should undergo rigorous evaluation [3]. Journal of the American Osteopathic Association. 2002;102(4):204-205. Date of Publication: 2002 2002;(4):204–5. [pmid: 12003464].
Farmer JA, Gotto AM Jr. Choosing the right lipid-regulating agent. A guide to selection. [Review] [59 refs]. Drugs. Nov. 1996;52(5):649-61. [pmid: 9118815].
Feehally J. Immunoglobulin A nephropathy: fish oils and beyond. [Review] [27 refs]. Curr Opin Nephrol Hypertens. Sep. 1996;5(5):442-6. [pmid: 8937814].
Fetterman JW Jr, Zdanowicz MM. Therapeutic potential of n-3 polyunsaturated fatty acids in disease. [Review] [98 refs]. Am J Health-Syst Pharm. Jul. 1. 2009;66(13):1169-79. [pmid: 19535655].
Fluri S, Wolf R, Leibundgut K, et al. Hemorrhage in vitamin K deficiency--a preventable entity. [German]. Praxis (Bern 1994). Apr. 11. 2007;96(15):597-600. [pmid: 17506390].
Flynn T, Stevermer JJ. Vitamin E does not prevent cardiovascular events in high-risk patients. J Fam Pract. Apr. 2000;49(4):372-3. [pmid: 10778845].
Ford SK, Misita CP, Shilliday BB, et al. Prospective study of supplemental vitamin K therapy in patients on oral anticoagulants with unstable international normalized ratios. J Thromb Thrombolysis. Aug. 2007;24(1):23-7. [pmid: 17323135].
Franco V, Polanczyk CA, Clausell N, et al. Role of dietary vitamin K intake in chronic oral anticoagulation: prospective evidence from observational and randomized protocols. Am J Med. May. 15. 2004;116(10):651-6. [pmid: 15121490].
Frishman WH, Grattan JG, Mamtani R, et al. Alternative and complementary medical approaches in the prevention and treatment of cardiovascular disease. Curr Probl Cardiol. 2005;30(8):381-459.
Fromm MF, Darbar D, Dell’Orto S, et al. Modulation of effect of dietary salt on prehepatic first-pass metabolism: effects of beta-blockade and intravenous salt loading. J Pharmacol Exp Ther. Jul. 1999;290(1):253-8. [pmid: 10381784].
Fugh-Berman A. Herb-drug interactions. [Review] [65 refs][Erratum appears in Lancet 2000 Mar 18;355(9208):1020]. Lancet. Jan. 8. 2000;355(9198):134-8. [pmid: 10675182].
Galli C. Lipid lowering drugs and polyunsaturated fatty acids. Nutrition, Metabolism and Cardiovascular Diseases. 2005;15(1):3-5. Date of Publication: February 2005 2005;(1):3–5.
Garber AJ. Attenuating cardiovascular risk factors in patients with type 2 diabetes. [Review] [38 refs]. Am Fam Phys. 2000;62(12):2633-42. [pmid: 11142470].
Gardner C, Messina M, Lawson LD, et al. Soy, garlic, and ginkgo biloba: Their potential role in cardiovascular disease prevention and treatment. Current Atherosclerosis Reports. 2003;5(6):468-475. Date of Publication: Nov 2003 2003;(6):468–75. [pmid: 14525680].
Gardner SF, Marx MA, White LM, et al. Combination of low-dose niacin and pravastatin improves the lipid profile in diabetic patients without compromising glycemic control. Ann Pharmacother. Jun. 1997;31(6):677-82. [pmid: 9184704].
Garnett WR. Interactions with hydroxymethylglutaryl-coenzyme A reductase inhibitors. [Review] [44 refs]. Am J Health-Syst Pharm. Aug. 1. 1995;52(15):1639-45. [pmid: 7583826].
Garrett R. Response [3]. Advanced Studies in Medicine. 2005;5(10):546.
Gattuso JM, Kamm MA. Adverse effects of drugs used in the management of constipation and diarrhoea. [Review] [150 refs]. Drug Saf. Jan. 1994;10(1):47-65. [pmid: 8136086].
Gaytan RJ, Prisant LM. Oral nutritional supplements and heart disease: a review. American journal of therapeutics. 2001;8(4):255-274. Date of Publication: 2001 Jul–Aug 2001;(4):255–74. [pmid: 11441326].
Geelen A, Brouwer IA, Zock PL, et al. Antiarrhythmic effects of n-3 fatty acids: evidence from human studies. [Review] [60 refs]. Curr Opin Lipidol. Feb. 2004;15(1):25-30. [pmid: 15166805].
Gericke D. Myocardial infarct: bolus time frame. When and how is magnesium therapy effective?. [German]. Fortschr Med Orig. Sep. 10. 1996;114(25):58. [pmid: 8974982].
Gerstein HC, Bosch J, Pogue J, et al. Rationale and design of a large study to evaluate the renal and cardiovascular effects of an ACE inhibitor and vitamin E in high-risk patients with diabetes. The MICRO-HOPE Study. Microalbuminuria, cardiovascular, and renal outcomes. Heart Outcomes Prevention Evaluation. Diabetes Care. Nov. 1996;19(11):1225-8. [pmid: 8908384].
Gharavi AG, Diamond JA, Smith DA, et al. Niacin-induced myopathy. [Review] [11 refs]. Am J Cardiol. Oct. 15. 1994;74(8):841-2. [pmid: 7942568].
Gille A, Bodor ET, Ahmed K, et al. Nicotinic acid: pharmacological effects and mechanisms of action. [Review] [123 refs]. Annu Rev Pharmacol Toxicol. 2008;48:79-106. [pmid: 17705685].
Ginsberg HN. Niacin in the metabolic syndrome: more risk than benefit?. Nature clin. Jun. 2006;2(6):300-1. [pmid: 16932303].
Gladdish S, Rajkumar C. Prevention of cardiac disease in the elderly. [Review] [61 refs]. J Cardiovasc Risk. Oct. 2001;8(5):271-7. [pmid: 11702032].
Goebel R. Diet supplements versus drugs. [German]. Pharmazeutische Zeitung. 2010;155(30).
Gold JL, Laxer DA, Dergal JM, et al. Herbal-drug therapy interactions: a focus on dementia. [Review] [47 refs]. Curr Opin Clin Nutr Metab Care. Jan. 2001;4(1):29-34. [pmid: 11122556].
Gold PE, Cahill L, Wenk GL. The lowdown on Ginkgo biloba. Sci Am. Apr. 2003;288(4):86-91. [pmid: 12661320].
Goldberg AC. A meta-analysis of randomized controlled studies on the effects of extended-release niacin in women. Am J Cardiol. Jul. 1. 2004;94(1):121-4. [pmid: 15219522].
Goldberg RB, Sabharwal AK. Fish oil in the treatment of dyslipidemia. [Review] [48 refs]. Curr. Apr. 2008;15(2):167-74. [pmid: 18316953].
Goldberg RB, Jacobson TA. Effects of niacin on glucose control in patients with dyslipidemia. [Review] [49 refs]. Mayo Clin Proc. Apr. 2008;83(4):470-8. [pmid: 18380993].
Goldstein MR, Mascitelli L, Pezzetta F. Periodontitis, atherosclerotic cardiovascular disease and vitamin D. Am J Cardiol. Oct. 15. 2009;104(8):1164. [pmid: 19801046].
Goodnight SH, Cairns JA, Fisher M, et al. Assessment of the therapeutic use of n-3 fatty acids in vascular disease and thrombosis. [Review] [107 refs]. Chest. Oct. 1992;102(4 Suppl):374S-84S. [pmid: 1395822].
Grundy SM. N-3 fatty acids: priority for post-myocardial infarction clinical trials. Circ Cardiovasc Qual Outcomes. Apr. 15. 2003;107(14):1834-6. [pmid: 12695281].
Guay DR. Are there alternatives to the use of quinine to treat nocturnal leg cramps?. [Review] [72 refs]. Consult Pharm. Feb. 2008;23(2):141-56. [pmid: 18454580].
Gulseth MP, Grice GR, Dager WE. Pharmacogenomics of warfarin: uncovering a piece of the warfarin mystery. [Review] [75 refs]. Am J Health-Syst Pharm. Jan. 15. 2009;66(2):123-33. [pmid: 19139476].
Gupta A, Morris G. Major aphthous ulcers induced by nicorandil. [Review] [11 refs]. Age Ageing. Jul. 2000;29(4):372-3. [pmid: 10985455].
Gurewich V. Guidelines for the management of anticoagulant therapy. [Review] [115 refs]. Semin Thromb Hemost. Jan. 1976;2(3):176-96. [pmid: 798275].
Guyton JR, Bays HE. Safety considerations with niacin therapy. [Review] [62 refs]. Am J Cardiol. Mar. 2007;99(6A):22C-31C. [pmid: 17368274].
Gylling H, Miettinen TA. Combination therapy with statins. Curr Opin Invest Drugs. 2002;3(9):1318-23.
Haan J, Hörr R. Delay in progression of dependency and need of care of dementia patients treated with Ginkgo special extract EGb 761. [German]. Wien Med Wochenschr. Nov. 2004;154(21–22):511-4. [pmid: 15638069].
Hageman GJ, Stierum RH. Niacin, poly(ADP-ribose) polymerase-1 and genomic stability. [Review] [88 refs]. Mutat Res. Apr. 18. 2001;475(1–2):45-56. [pmid: 11295153].
Haglund O. Effects of fish oil on risk factors for cardiovascular disease. Minireview based on a doctoral thesis. [Review] [198 refs]. Ups J Med Sci. 1993;98(2):89-148. [pmid: 8184521].
Haller CA. Clinical approach to adverse events and interactions related to herbal and dietary supplements. Clinical Toxicology. 2006;44(5):605-610. Date of Publication: 01 Jun 2006 2006;(5):605–10. [pmid: 16905502].
Hamilton CA, Miller WH, Al-Benna S, et al. Strategies to reduce oxidative stress in cardiovascular disease. [Review] [204 refs]. Clin Sci (Colch). Mar. 2004;106(3):219-34. [pmid: 14733610].
Hansen JB, Huseby NE, Sandset PM, et al. Tissue-factor pathway inhibitor and lipoproteins. Evidence for association with and regulation by LDL in human plasma. Arterioscler Thromb. Feb. 1994;14(2):223-9. [pmid: 8305412].
Harper CR, Jacobson TA. The broad spectrum of statin myopathy: from myalgia to rhabdomyolysis. [Review] [36 refs]. Curr Opin Lipidol. Aug. 2007;18(4):401-8. [pmid: 17620856].
Harris JE. Interaction of dietary factors with oral anticoagulants: review and applications. [Review] [76 refs]. J Am Diet Assoc. May. 1995;95(5):580-4. [pmid: 7722194].
Harris WS. Expert opinion: omega-3 fatty acids and bleeding-cause for concern?. [Review] [26 refs]. Am J Cardiol. Mar. 2007;99(6A):44C-6C. [pmid: 17368278].
Harrison N, Abhyankar B. The mechanism of action of omega-3 fatty acids in secondary prevention post-myocardial infarction. Current Medical Research and Opinion. 2005;21(1):95-100. Date of Publication: Jan 2005 2005;(1):95–100. [pmid: 15881480].
Hasani-Ranjbar S, Nayebi N, Larijani B, et al. A systematic review of the efficacy and safety of herbal medicines used in the treatment of obesity. World Journal of Gastroenterology. 2009;15(25):3073-3085. Date of Publication: 07 Jul 2009 2009;(25):3073–85. [pmid: 19575486].
Hassan KS, Hassan SK, Hijazi EG, et al. Effects of omega-3 on lipid profile and inflammation markers in peritoneal dialysis patients. Renal Failure. 2010;32(9):1031-1035. Date of Publication: 2010 2010;(9):1031–5. [pmid: 20863205].
Hathcock JN. Vitamins and minerals: efficacy and safety. [Review] [152 refs]. Am J Clin Nutr. Aug. 1997;66(2):427-37. [pmid: 9250127].
Heck AM, DeWitt BA, Lukes AL. Potential interactions between alternative therapies and warfarin. [Review] [66 refs]. Am J Health-Syst Pharm. Jul. 1. 2000;57(13):1221-7. [pmid: 10902065].
Heemskerk JW, Vossen RC, van Dam-Mieras MC. Polyunsaturated fatty acids and function of platelets and endothelial cells. [Review] [40 refs]. Curr Opin Lipidol. Feb. 1996;7(1):24-9. [pmid: 8925184].
Hennekens CH. Antioxidant vitamins and cardiovascular disease: current perspectives and future directions. Eur Heart J. Feb. 1997;18(2):177-9. [pmid: 9043828].
Hirano M, Quinzii CM, DiMauro S. Restoring balance to ataxia with coenzyme Q_10_ deficiency. J Neurol Sci. 2006;246(1–2):11-2. [pmid: 16678207].
Hirsh J. Optimal intensity and monitoring warfarin. [Review] [14 refs]. Am J Cardiol. Feb. 23. 1995;75(6):39B-42B. [pmid: 7863972].
Hogg RJ. A randomized, placebo-controlled, multicenter trial evaluating alternate-day prednisone and fish oil supplements in young patients with immunoglobulin A nephropathy. Scientific Planning Committee of the IgA Nephropathy Study. Am J Kidney Dis. Nov. 1995;26(5):792-6. [pmid: 7485134].
Holbrook AM, Pereira JA, Labiris R, et al. Systematic overview of warfarin and its drug and food interactions. [Review] [248 refs]. Arch Intern Med. May. 23. 2005;165(10):1095-106. [pmid: 15911722].
Holtmeier HJ. Diuretics and diet in hypertension with special reference to magnesium deficiency. [German]. Dtsch Med J. Mar. 1969;20(5):141-50. [pmid: 5788084].
Holub DJ, Holub BJ. Omega-3 fatty acids from fish oils and cardiovascular disease. [Review] [51 refs]. Mol Cell Biochem. Aug. 2004;263(1–2):217-25. [pmid: 15524182].
Holubarsch CJ. Evidence-based medicine with hawthorn extract. [Review] [33 refs] [German]. Pharm Unserer Zeit. 2005;34(1):58-64. [pmid: 15700797].
Holzgreve H. Therapy of cardiac insufficiency with diuretics. [German]. Fortschr Med Orig. Aug. 26. 1982;100(31–32):1449-56. [pmid: 7129304].
Horner SM. Magnesium and arrhythmias in acute myocardial infarction. [Review] [66 refs]. Coron Artery Dis. May. 1996;7(5):359-63. [pmid: 8866201].
Horwitt MK. Therapeutic uses of vitamin E in medicine. [Review] [86 refs]. Nutr Rev. Mar. 1980;38(3):105-13. [pmid: 6990312].
Howe PR. Dietary fats and hypertension. Focus on fish oil. [Review] [96 refs]. Ann New York Acad Sci. Sep. 20. 1997;827:339-52. [pmid: 9329766].
Hu Z, Yang X, Ho PC, et al. Herb-drug interactions: a literature review. [Review] [505 refs]. Drugs. 2005;65(9):1239-82. [pmid: 15916450].
Ioannides C. Drug-phytochemical interactions. Inflammopharmacology. 2003;11(1):7-42. [pmid: 15035733].
Irish A, Dogra G, Mori T, et al. Preventing AVF thrombosis: the rationale and design of the Omega-3 fatty acids (Fish Oils) and Aspirin in Vascular access OUtcomes in REnal Disease (FAVOURED) study. BMC Nephrol. 2009;10:1. [pmid: 19159453].
Israili ZH, Hernández-Hernández R, Valasco M. The future of antihypertensive treatment. [Review] [164 refs]. Am J Ther. Mar. 2007;14(2):121-34. [pmid: 17414579].
Janero DR. Therapeutic potential of vitamin E in the pathogenesis of spontaneous atherosclerosis. [Review] [193 refs]. Free Radic Biol Med. 1991;11(1):129-44. [pmid: 1937126].
Janetzky K, Morreale AP. Probable interaction between warfarin and ginseng. Am J Health-Syst Pharm. 1997;54(6):692-3. [pmid: 9075501].
Kaikkonen J, Tuomainen TP, Nyyssonen K, et al. Coenzyme Q10: absorption, antioxidative properties, determinants, and plasma levels. Free Radic Res. Apr. 2002;36(4):389-97. [pmid: 12069102].
Kaul N, Devaraj S, Jialal I. Alpha-tocopherol and atherosclerosis. [Review] [100 refs]. Exp Biol Med (Maywood). Jan. 2001;226(1):5-12. [pmid: 11368238].
Keaney JF Jr, Vita JA. Vascular oxidative stress and antioxidant protection in atherosclerosis: what do the clinical trials say?. [Review] [89 refs]. J Cardiopulm Rehabil. Jul. 2002;22(4):225-33. [pmid: 12202841].
Kendler BS. Garlic (Allium sativum) and onion (Allium cepa): a review of their relationship to cardiovascular disease. [Review] [116 refs]. Prev Med. Sep. 1987;16(5):670-85. [pmid: 3317392].
Kendler BS. Supplemental conditionally essential nutrients in cardiovascular disease therapy. The Journal of cardiovascular nursing. 2006;21(1):9-16. Date of Publication: 2006 Jan–Feb 2006;(1):9–16. [pmid: 16407731].
Keren A, Tzivoni D. Magnesium therapy in ventricular arrhythmias. [Review] [113 refs]. Pacing Clin Electrophysiol. Jul. 1990;13(7):937-45. [pmid: 1695751].
Kinsella JE. Effects of polyunsaturated fatty acids on factors related to cardiovascular disease. [Review] [87 refs]. Am J Cardiol. Oct. 30. 1987;60(12):23G-32G. [pmid: 2886042].
Klepser TB, Berryhill B, Dixon K, et al. Evaluation of Dietary Supplements with Claims of Antimicrobial Activity. Journal of Infectious Disease Pharmacotherapy. 2003;6(3):1-29. Date of Publication: 2003 2003;(3):1–29.
Klupp NL, Chang D, Hawke F, et al. Ganoderma lucidum for the treatment of cardiovascular risk factors [protocol for a Cochrane review]. Cochrane Database of Systematic Reviews. Chichester (UK). John Wiley & Sons, Ltd. 2008. 2008;(3):3.
Knoke JD. Letter: Statistical analysis of treatment with vitamin E. N Engl J Med. Jan. 24. 1974;290(4):231-2. [pmid: 4203008].
Ko R. Safety of ethnic & imported herbal and dietary supplements. Clinical Toxicology. 2006;44(5):611-616. Date of Publication: 01 Jun 2006 2006;(5):611–6. [pmid: 16905503].
Komaroff AL. By the way, doctor. I’ve been taking omega-3 fats and have two big bruises. Even small doses of aspirin cause me to bruise. My doctor is not concerned, but should I be?. Harv Health Lett. Apr. 2009;34(6):8. [pmid: 19469011].
Kowluru RA, Kennedy A. Therapeutic potential of anti-oxidants and diabetic retinopathy. [Review] [123 refs]. Expert Opin Investig Drugs. Sep. 2001;10(9):1665-76. [pmid: 11772276].
Kreisberg RA. Niacin: a therapeutic dilemma. "One man’s drink is another’s poison". [Review] [34 refs]. Am J Med. Oct. 1994;97(4):313-6. [pmid: 7942931].
Kuhn MA. Herbal remedies: drug-herb interactions. [Review] [51 refs]. Crit Care Nurse. Mar. 1930;22(2):22-8. [pmid: 11961942].
Kumar A, Kaur H, Devi P, et al. Role of coenzyme Q10 (CoQ10) in cardiac disease, hypertension and Meniere-like syndrome. Pharmacology and Therapeutics. 2009;124(3):259-68. [pmid: 19638284].
Kumar A, Kaur H, Devi P, et al. Role of coenzyme Q10 (CoQ10) in cardiac disease, hypertension and Meniere-like syndrome. [Review] [86 refs]. Pharmacol Ther. Dec. 2009;124(3):259-68. [pmid: 19638284].
Kurowska EM. Nitric oxide therapies in vascular diseases. [Review] [124 refs]. Curr Pharm Des. 2002;8(3):155-66. [pmid: 11812265].
Kwan D, Beyene J, Shah PS. Adverse consequences of internet purchase of pharmacologic agents or dietary supplements. Journal of Pharmacy Technology. 2009;25(6):355-360. Date of Publication: November–December 2009 2009;(6):355–60.
Lalukota K, Cleland JG, Ingle L, et al. Clinical trials update from the Heart Failure Society of America: EMOTE, HERB-CHF, BEST genetic sub-study and RHYTHM-ICD. [Review] [13 refs]. Eur J Heart Fail. Dec. 2004;6(7):953-5. [pmid: 15556058].
Landgraf R. PUFA supplementation and hypertension in type 1 diabetes. Annals of the New York Academy of Sciences. 1993;683:331-336. Date of Publication 1993 1993;(331):6. [pmid: 8352455].
Landmark K, Thaulow E, Hysing J, et al. Effects of fish oil, nifedipine and their combination on blood pressure and lipids in primary hypertension. J Hum Hypertens. Feb. 1993;7(1):25-32. [pmid: 8450517].
Langsjoen PH, Langsjoen AM. Overview of the use of CoQ10 in cardiovascular disease. [Review] [92 refs]. Biofactors. 1999;9(2–4):273-84. [pmid: 10416041].
Lavie CJ, Milani RV. Efficacy and safety of sustained-release niacins. Am J Health-Syst Pharm. 2011;68(14):1294-5. [pmid: 21719588].
Lengfelder W. Antioxidative vitamins: prevention of cardiovascular diseases. [Review] [16 refs] [German]. Dtsch Med Wochenschr. Aug. 21. 1998;123(34–35):1014-7. [pmid: 9739768].
Lerman RH. Essential fatty acid. Integrative Medicine. 2006;5(3):34-44. Date of Publication: Jun 2006 2006;(3):34–44.
Leung VW, Shalansky SJ, Lo MK, et al. Prevalence of use and the risk of adverse effects associated with complementary and alternative medicine in a cohort of patients receiving warfarin. Ann Pharmacother. May. 2009;43(5):875-81. [pmid: 19401475].
Levine MN. Nonhemorrhagic complications of anticoagulant therapy. Semin Thromb Hemost. Jan. 1986;12(1):63-6. [pmid: 3961507].
Levitan EB, Judd SE. Can vitamin D supplementation improve physical function and quality of life in older patients with heart failure?. Circ. Mar. 2010;3(2):183-4. [pmid: 20233991].
Levy Y, Blum S, Levy AP. Antioxidants in the prevention of atherosclerosis: The importance of proper patient selection. Clinical Nutrition. 2009;28(5):581-582. Date of Publication: October 2009 2009;(5):581–2. [pmid: 19464773].
Lewis WH. Iatrogenic psychotic depressive reaction in hypertensive patients. Am J Psychiatry. Apr. 1971;127(10):1416-7. [pmid: 5549939].
Li B, Zhu W-L, Chen K-X. Advances in the study of berberine and its derivatives. Yaoxue Xuebao. 2008;43(8):773-87.
Liatsos G, Elefsiniotis I, Todorova R, et al. Severe thrombotic thrombocytopenic purpura (TTP) induced or exacerbated by the immunostimulatory herb Echinacea. [Erratum appears in Am J Hematol. 2006 Sep;81(9):722 Note: George, Liatsos [corrected to Liatsos, George]; Ioannis, Elefsiniotis [corrected to Elefsiniotis, Ioannis]; Radostina, Todorova [corrected to Todorova, Radostina]; Antonios, Moulakakis [corrected to Moulakakis, Antonios]]. Am J Hematol. Mar. 2006;81(3):224. [pmid: 16493617].
Lieberman R. Statins and coenzyme Q_10_: Intersection of established medical therapeutics, clinical pharmacology and the emerging evidence-based science of complementary and alternative medicine for protecting cardiovascular health. Current Topics in Nutraceutical Research. 2005;3(3):163-166. Date of Publication: Aug 2005 2005;(3):163–6.
Lindheimer MD, Davison JM. Introduction new developments in preeclampsia. Seminars in Nephrology. 2004;24(6 SPEC ISS):537-539. Date of Publication: Nov 2004 2004'(6 SPEC.ISS.):537–9.
Lipworth BJ, McDevitt DG, Struthers AD. Electrocardiographic changes induced by inhaled salbutamol after treatment with bendrofluazide: effects of replacement therapy with potassium, magnesium and triamterene. Clin Sci (Colch). Mar. 1990;78(3):255-9. [pmid: 2156644].
Littarru GP, Tiano L. Clinical aspects of coenzyme Q10: an update. [Review] [49 refs]. Nutrition. Mar. 2010;26(3):250-4. [pmid: 19932599].
Liu T, Li G. Anti-inflammatory effects of long-chain omega 3 fatty acids: potential benefits for atrial fibrillation. Med Hypotheses. 2005;65(1):200-1. [pmid: 15893149].
Love DG. Management of hemorrhagic events in patients receiving anticoagulant therapy. J Thromb Thrombolysis. Apr. 1999;7(2):149-52. [pmid: 10364766].
Lundberg GD. Therapeutic lifestyle changes and supplements outperform a statin. MedGenMed Medscape General Medicine. 2008;10(10):227.
Lüderitz B. Magnesium in myocardial infarct. [German]. Dtsch Med Wochenschr. Aug. 5. 1994;119(31–32):1102-3. [pmid: 8055754].
Ly J, Percy L, Dhanani S. Use of dietary supplements and their interactions with prescription drugs in the elderly. American Journal of Health-System Pharmacy. 2002;59(18):1759-1762. Date of Publication: 15 Sep 2002 2002;(18):1759–62. [pmid: 12298114].
Mahadevan S, Park Y. Multifaceted therapeutic benefits of Ginkgo biloba L.: chemistry, efficacy, safety, and uses. [Review] [86 refs]. J Food Sci. Jan. 2008;73(1):R14-19. [pmid: 18211362].
Malminiemi K, Palomäki A, Malminiemi O. Comparison of LDL trap assay to other tests of antioxidant capacity; effect of vitamin E and lovastatin treatment. Free Radic Res. Nov. 2000;33(5):581-93. [pmid: 11200090].
Mansoor GA. Herbs and alternative therapies in the hypertension clinic. [Review] [39 refs]. Am J Hypertens. Sep. 2001;14(9 Pt 1):971-5. [pmid: 11587167].
Manz M, Susilo R. Therapy of cardiac arrhythmias. Clinical significance of potassium- and magnesium aspartate in arrhythmias. [German]. Fortschr Med Orig. Originalien. 2002;(1):11-5. [pmid: 14518352].
Marchioli R, Silletta MG, Levantesi G, et al. N-3 polyunsaturated fatty acids in heart failure: mechanisms and recent clinical evidence. Cell Mol Biol (Noisy-le-grand). 2010;56(1):110-30. [pmid: 20196975].
Margolis KL, Ray RM, Kerby TJ. The womens health initiative calcium/vitamin D trial. Hypertension. 2011;57(4):e14. [pmid: 21357276].
Mark DA. All red yeast rice products are not created equal - Or legal. Am J Cardiol. 2010;106(3):448. [pmid: 20643262].
Mashour NH, Lin GI, Frishman WH. Herbal medicine for the treatment of cardiovascular disease: clinical considerations. [Review] [125 refs]. Arch Intern Med. Nov. 9. 1998;158(20):2225-34. [pmid: 9818802].
Mason DT, Braunwald E. Digitalis: new facts about an old drug. [Review] [65 refs]. Am J Cardiol. Aug. 1968;22(2):151-61. [pmid: 4874956].
Mason P. Potential uses for coenzyme Q10. Pharmaceutical Journal. 2005;275(7368):379-382. Date of Publication: 24 Sep 2005 2005;(7368):379–82.
Matz R. Magnesium and hypertension. J Am Geriatr Soc. Apr. 1993;41(4):468-9. [pmid: 8463545].
Mauskop A, Altura BM. Role of magnesium in the pathogenesis and treatment of migraines. [Review] [36 refs]. Clin Neurosci. 1998;5(1):24-7. [pmid: 9523054].
Mauskop A. Complementary and alternative treatments for migraine. Drug Development Research. 2007;68(7):424-427. Date of Publication: Dec 2007 2007;(7):424–7.
May GS, Eberlein KA, Furberg CD, et al. Secondary prevention after myocardial infarction: a review of long-term trials. [Review] [84 refs]. Prog Cardiovasc Dis. Jan. 1982;24(4):331-52. [pmid: 6119737].
May GS, Furberg CD, Eberlein KA, et al. Secondary prevention after myocardial infarction: a review of short-term acute phase trials. [Review] [148 refs]. Prog Cardiovasc Dis. Jan. 1983;25(4):335-59. [pmid: 6129678].
McCabe S. Complementary herbal and alternative drugs in clinical practice. Perspectives in Psychiatric Care. 2002;38(3):98-107. Date of Publication: July/September 2002 2002;(3):98–107. [pmid: 12385080].
McCann JC, Ames BN. Vitamin K, an example of triage theory: is micronutrient inadequacy linked to diseases of aging?. [Review] [346 refs]. Am J Clin Nutr. Oct. 2009;90(4):889-907. [pmid: 19692494].
McClaskey EM, Michalets EL. Subdural hematoma after a fall in an elderly patient taking high-dose omega-3 fatty acids with warfarin and aspirin: Case report and review of the literature. Pharmacotherapy. 2007;27(1):152-60. [pmid: 17192169].
McCord J, Borzak S. Magnesium for myocardial infarction?. [Review] [9 refs]. Hosp Pract (Off Ed). Sep. 5. 1953;29(8):47-9. [pmid: 8056858].
McCormack PL, Keating GM. Prolonged-release nicotinic acid: a review of its use in the treatment of dyslipidaemia. [Review] [55 refs]. Drugs. 2005;65(18):2719-40. [pmid: 16392885].
McGowan MP, Proulx S. Nutritional supplements and serum lipids: does anything work?. [Review] [46 refs]. Curr Atheroscler Rep. Nov. 2009;11(6):470-6. [pmid: 19852889].
McLean RM. Magnesium and its therapeutic uses: a review. [Review] [130 refs]. Am J Med. Jan. 1994;96(1):63-76. [pmid: 8304365].
McLeod AA. Later management of documented ischaemic heart disease: secondary prevention and rehabilitation. [Review] [91 refs]. Br Med Bull. 2001;59:113-33. [pmid: 11756207].
McQueen MJ, Lonn E, Gerstein HC, et al. The HOPE (Heart Outcomes Prevention Evaluation) Study and its consequences. Scand J Clin Lab Invest Suppl. 2005;240:143-56. [pmid: 16112972].
Meagher E, Rader DJ. Antioxidant therapy and atherosclerosis: animal and human studies. [Review] [28 refs]. Trends Cardiovasc Med. Apr. 2001;11(3–4):162-5. [pmid: 11686007].
Meagher EA. Treatment of atherosclerosis in the new millennium: is there a role for vitamin E?. [Review] [62 refs]. Prev Cardiol. 2003;6(2):85-90. [pmid: 12732794].
Melzer J, Iten E, Saller R. Crataegus berries: heart complaints, congestive heart failure NYHA I and II. A systematic review (Provisional abstract). Perfusion. 2003;16:358-62.
Michaud LB, Karpinski JP, Jones KL, et al. Dietary supplements in patients with cancer: risks and key concepts, part 2. [Review] [115 refs]. Am J Health-Syst Pharm. Mar. 1. 2007;64(5):467-80. [pmid: 17322159].
Milan A, Mulatero P, Rabbia F, et al. Salt intake and hypertension therapy. [Review] [35 refs]. JN, J. Jan. 2002;15(1):1-6. [pmid: 11936420].
Miller KL, Liebowitz RS, Newby LK. Complementary and alternative medicine in cardiovascular disease: A review of biologically based approaches. Am Heart J. 2004;147(3):401-11. [pmid: 14999187].
Mishkel GJ, Cairns JA. Cardiovascular effects of omega-3 polyunsaturated fatty acids (fish oils). [Review] [106 refs]. Baillieres Clin Haematol. Jul. 1990;3(3):625-49. [pmid: 2271785].
Moe SM. Vitamin D, cardiovascular disease, and survival in dialysis patients. [Review] [32 refs]. J Bone Miner Res. Dec. Suppl 2. 2007;22:V95-99. [pmid: 18290731].
Mordasini R, Oster P, Riesen W. Dietary and drug treatment of hyperlipoproteinemia. [Review] [41 refs]. Ric Clin Lab. Jan. 1982;12(1):117-25. [pmid: 7046017].
Mori TA, Beilin LJ. Omega-3 fatty acids and inflammation. Current Atherosclerosis Reports. 2004;6(6):461-467. Date of Publication: Nov 2004 2004;(6):461–7. [pmid: 15485592].
Mortensen SA. Coenzyme Q10 as an adjunctive therapy in patients with congestive heart failure. J Am Coll Cardiol. Jul. 2000;36(1):304-5. [pmid: 10898453].
Moses G. Complementary and alternative medicine use in the elderly. Journal of Pharmacy Practice and Research. 2005;35(1):63-68. Date of Publication: Mar 2005 2005;(1):63–8.
Mosher LR. Nicotinic acid side effects and toxicity: a review. [Review] [47 refs]. Am J Psychiatry. Mar. 1970;126(9):1290-6. [pmid: 4905018].
Moyad MA. The use of complementary/preventive medicine to prevent prostate cancer recurrence/progression following definitive therapy. Part II--rapid review of dietary supplements. Curr Opin Urol. Mar. 2003;13(2):147-51. [pmid: 12584475].
Muller S-D. Omega-3 fatty acids in dietetics. A review (part 3). [German]. Schweiz Z GanzheitsMed. 2004;16(4):223-9.
Mundal HH, Gjesdal K, Landmark K. The effect of N-3 fatty acids and nifedipine on platelet function in hypertensive males. Thromb Res. Nov. 1. 1993;72(3):257-62. [pmid: 8303664].
Mutanen M, Freese R. Polyunsaturated fatty acids and platelet aggregation. [Review] [44 refs]. Curr Opin Lipidol. Feb. 1996;7(1):14-9. [pmid: 8925182].
Nakajima K. Pharmacotherapy of mixed dyslipidemia in the metabolic syndrome. [Review] [74 refs]. Curr Clin Pharmacol. May. 1. 2010;5(2):133-9. [pmid: 20156152].
Nambi V, Ballantyne CM. Combination therapy with statins and omega-3 fatty acids. [Review] [32 refs]. Am J Cardiol. Aug. 21. 2006;98(4A):34i-8i. [pmid: 16919515].
Nayak DU, Karmen C, Frishman WH, et al. Antioxidant vitamins and enzymatic and synthetic oxygen-derived free radical scavengers in the prevention and treatment of cardiovascular disease. [Review] [243 refs]. Heart Dis. Jan. 2001;3(1):28-45. [pmid: 11975768].
Nestel P. Linoleic acid reassessed. Curr Opin Lipidol. 2010;21(3):253-5. [pmid: 20224399].
Nguyen TT, Dale LC. Plant stanol esters and vitamin K. Mayo Clin Proc. Jun. 1999;74(6):642-3. [pmid: 10377943].
Nordøy A. Statins and omega-3 fatty acids in the treatment of dyslipidemia and coronary heart disease. [Review] [46 refs]. Minerva Med. Oct. 2002;93(5):357-63. [pmid: 12410168].
Normen L, Shaw CA, Fink CS, et al. Combination of phytosterols and omega-3 fatty acids: A potential strategy to promote cardiovascular health. Current Medicinal Chemistry: Cardiovascular and Hematological Agents. 2004;2(1):1-12. Date of Publication: Jan 2004 2004;(1):1–12. [pmid: 15320801].
Nowack R. Herb-drug interactions in nephrology: documented and theoretical. [Review] [23 refs]. Clin Nephrol. May. 2008;69(5):319-25. [pmid: 18538093].
Ntanios FY, Duchateau GS. A healthy diet rich in carotenoids is effective in maintaining normal blood carotenoid levels during the daily use of plant sterol-enriched spreads. [Review] [48 refs]. Int J Vitam Nutr Res. Jan. 2002;72(1):32-9. [pmid: 11887750].
Nugent AP, McKevith B. Fortified foods: Friend or foe?. Nutrition Bulletin. 2004;29(4):295-297. Date of Publication: Dec 2004 2004;(4):295–7.
O’Hara DA. Anesthetic implications of herbals and dietary supplements: Part I. Progress in Anesthesiology. 2003;17(10):151-158. Date of Publication: May 2003 2003;(10):151–8.
O’Reilly RA, Rytand DA. "Resistance" to warfarin due to unrecognized vitamin K supplementation. N Engl J Med. Jul. 17. 1980;303(3):160-1. [pmid: 7383081].
Ohnishi N, Yokoyama T. Interactions between medicines and functional foods or dietary supplements. Keio Journal of Medicine. 2004;53(3):137-150. Date of Publication: Sep 2004 2004;(3):137–50. [pmid: 15477727].
Okuyama H, Ichikawa Y, Sun Y, et al. Omega3 fatty acids effectively prevent coronary heart disease and other late-onset diseases--the excessive linoleic acid syndrome. World Rev Nutr Diet. 2007;96:83-103. [pmid: 17167282].
Ong HT, Cheah JS. Statin alternatives or just placebo: an objective review of omega-3, red yeast rice and garlic in cardiovascular therapeutics. [Review] [59 refs]. Chin Med J. Aug. 20. 2008;121(16):1588-94. [pmid: 18982874].
Orlov MV, Brodsky MA, Douban S. A review of magnesium, acute myocardial infarction and arrhythmia. [Review] [67 refs]. J Am Coll Nutr. Apr. 1994;13(2):127-32. [pmid: 8006293].
Ortiz BI, Shields KM, Clauson KA, et al. Complementary and alternative medicine use among Hispanics in the United States. Annals of Pharmacotherapy. 2007;41(6):994-1004. Date of Publication: Jun 2007 2007;(6):994–1004. [pmid: 17504837].
Overvad K, Diamant B, Holm L, et al. Coenzyme Q10 in health and disease. European journal of clinical nutrition. 1999;53(10):764-770. Date of Publication: Oct 1999 1999;(10):764–70. [pmid: 10556981].
Palmer ME. Effect of dietary supplements on hemostasis: A case of bleeding in context of research and surveillance. Thrombosis Research. 2005;117(1–2):33-38. Date of Publication 2005 2005;(1–2):33–8. [pmid: 16182344].
Papanikitas A. The second-hand truth. British Journal of General Practice. 2009;59(567):781. Date of Publication: October 2009 2009;(567):781.
Parashar A. N-3 polyunsaturated fatty acids and statins in heart failure. La 1f40 ncet. Jan. 31. 2009;373(9661):379-1. [pmid: 19186266].
Parthasarathy S, Khan-Merchant N, Penumetcha M, et al. Did the antioxidant trials fail to validate the oxidation hypothesis?. [Review] [66 refs]. Curr Atheroscler Rep. Sep. 2001;3(5):392-8. [pmid: 11487450].
Passeri M, Provvedini D. Vitamins: their relationship to atherosclerosis. [Review] [96 refs]. Acta Vitaminol Enzymol. 1982;4(1–2):169-77. [pmid: 6751050].
Pearce SHS, Cheetham TD. Diagnosis and management of vitamin D deficiency. BMJ. 2010;340(7738):142-147. Date of Publication: 16 Jan 2010 2010;(7738)142–7.
Peck MD. Omega-3 polyunsaturated fatty acids: benefit or harm during sepsis?. [Review] [68 refs]. New Horiz. May. 1994;2(2):230-6. [pmid: 7922448].
Pelton R. Nutrients shown to improve patients’ heart health. American Druggist. 54. 215(3):52-1998. Date of Publication: 1998 1998;(3):52+54.
Peng CC, Glassman PA, Trilli LE, et al. Incidence and Severity of Potential Drug-Dietary Supplement Interactions in Primary Care Patients: An Exploratory Study of 2 Outpatient Practices. Archives of Internal Medicine. 2004;164(6):630-636. Date of Publication: 22 Mar 2004 2004;(6);630–6. [pmid: 15037491].
Pepe S, Marasco SF, Haas SJ, et al. Coenzyme Q10 in cardiovascular disease. [Review] [150 refs]. Mitochondrion. Jun. Suppl. 2007;7:S154-167. [pmid: 17485243].
Phillips AW, Osborne JA. Survey of alternative and nonprescription therapy use [1]. Am J Health-Syst Pharm. 2000;57(14):1361-2. [pmid: 10918928].
Pieper JA. Understanding niacin formulations. [Review] [14 refs]. Am J Manag Care. Sep. 2002;8(12 Suppl):S308-314. [pmid: 12240702].
Pindur G, Mörsdorf S. The use of prothrombin complex concentrates in the treatment of hemorrhages induced by oral anticoagulation. [Review] [20 refs]. Thromb Res. Aug. 15. 1999;95(4 Suppl 1):S57-61. [pmid: 10499910].
Pittler MH, Ernst E. Complementary therapies for neuropathic and neuralgic pain: Systematic review. Clinical Journal of Pain. 2008;24(8):731-733. Date of Publication: October 2008 2008;(8):731–3. [pmid: 18806539].
Pray WS. Nonprescription products to avoid with hypertension. U S Pharmacist. 2010;35(2).
Preuss HG, Bagchi D, Bagchi M. Protective effects of a novel niacin-bound chromium complex and a grape seed proanthocyanidin extract on advancing age and various aspects of syndrome X. [Review] [35 refs]. Ann New York Acad Sci. May. 2002;957:250-9. [pmid: 12074977].
Pruthi RK, Schmidt KA, Slaby JA, et al. Platelet dysfunction induced by herbal supplements in a patient with mild hemophilia A. J Thromb Haemost. Dec. 2007;5(12):2556-8. [pmid: 17877787].
Pryor WA. Vitamin E and heart disease: basic science to clinical intervention trials. [Review] [244 refs]. Free Radic Biol Med. Jan. 1. 2000;28(1):141-64. [pmid: 10656300].
Quintanilla AP, Weffer MI. Hyperkalemia in the patient on chronic dialysis. Int J Artif Organs. Jan. 1987;10(1):17-9. [pmid: 3570539].
Rahman K. Historical perspective on garlic and cardiovascular disease. [Review] [29 refs]. J Nutr. Mar. 2001;131(3s):977S-9S. [pmid: 11238800].
Rahman K, Lowe GM. Garlic and cardiovascular disease: a critical review. [Review] [52 refs]. J Nutr. Mar. 2006;136(3 Suppl):736S-40S. [pmid: 16484553].
Rai J. Adverse interactions between low-dose aspirin/warfarin and garlic/ginseng/Ginkgo biloba. Indian Heart J. 2004;56(2):176-Apr. [pmid: 15377145].
Raitt MH. Are n-3 polyunsaturated fatty acids antiarrhythmic in the absence of ischemia? : EEEEditorial t"o: The role of n-3 PUFAs in preventing the arrhythmic risk in patients with idiopathic dilated cardiomyopa"thy by S. Nodari et al. Cardiovascular Drugs and Therapy. 2009;23(1):1-3. Date of Publication: February 2009 2009;(1):1–3. [pmid: 19005746].
Rauch B, Schiele R, Schneider S, et al. Highly purified omega-3 fatty acids for secondary prevention of sudden cardiac death after myocardial infarction-aims and methods of the OMEGA-study. Cardiovasc Drugs Ther. Oct. 2006;20(5):365-75. [pmid: 17124558].
Rebecca CR. Vitamins and minerals that affect hemostasis and antithrombotic therapies. Thrombosis Research. 2005;117(1–2):25-31. Date of Publication 2005 2005;(1–2):25–31. [pmid: 16257439].
Reeder GS. Adjunctive therapy in the management of patients with acute myocardial infarction. [Review] [14 refs]. Mayo Clin Proc. May. 1995;70(5):464-8. [pmid: 7731256].
Rees M. Alternative treatments for the menopause. Best Pract Res Clin Obstet Gynaecol. Feb. 2009;23(1):151-61. [pmid: 19010734].
Reid IR. Effects of calcium supplementation on circulating lipids: potential pharmacoeconomic implications. [Review] [34 refs]. Drugs & Aging. 2004;21(1):7-17. [pmid: 14715041].
Reid JL. Drug therapy in hypertension: risks and benefits. [Review] [26 refs]. J Clin Hypertens (Greenwich). Jun. 1986;2(2):183-8. [pmid: 3531419].
Reiffel JA, McDonald A. Antiarrhythmic effects of omega-3 fatty acids. [Review] [73 refs]. Am J Cardiol. Aug. 21. 2006;98(4A):50i-60i. [pmid: 16919517].
Rigelsky JM, Sweet BV. Hawthorn: pharmacology and therapeutic uses. [Review] [37 refs]. Am J Health-Syst Pharm. Mar. 1. 2002;59(5):417-22. [pmid: 11887407].
Righetti M. Protective effect of vitamin B therapy on bone and cardiovascular disease. [Review] [70 refs]. Recent Patents Cardiovasc Drug Discov. Jan. 2009;4(1):37-44. [pmid: 19149705].
Mörike EM. Vitamin E treatment of patients with 1f40 coronary disease (Cambridge Heart Antioxidant Study--CHAOS). [German]. Dtsch Med Wochenschr. May. 24. 1996;121(21):A9. [pmid: 8646973].
Robinson AW, Sloan HL, Arnold G. Use of niacin in the prevention and management of hyperlipidemia. [Review] [54 refs]. Prog Cardiovasc Nurs. 2001;16(1):14-20. [pmid: 11252872].
Roche HM, Gibney MJ. Long-chain n-3 polyunsaturated fatty acids and triacylglycerol metabolism in the postprandial state. [Review] [68 refs]. Lipids. Suppl. 1999;34:S259-265. [pmid: 10419173].
Rodrigo R, Cereceda M, Castillo R, et al. Prevention of atrial fibrillation following cardiac surgery: Basis for a novel therapeutic strategy based on non-hypoxic myocardial preconditioning. Pharmacology and Therapeutics. 2008;118(1):104-127. Date of Publication: Apr 2008 2008;(1):104–27. [pmid: 18346791].
Rodrigo R, Vinay J, Castillo R, et al. Use of vitamins C and E as a prophylactic therapy to prevent postoperative atrial fibrillation. [Review] [109 refs]. Int J Cardiol. Feb. 4. 2010;138(3):221-8. [pmid: 19446899].
Rohde LE, de Assis MC, Rabelo ER. Dietary vitamin K intake and anticoagulation in elderly patients. [Review] [39 refs]. Curr Opin Clin Nutr Metab Care. Jan. 2007;10(1):1-5. [pmid: 17143047].
Roland I, de L, X, Evrard B, et al. Modulation of the arachidonic cascade with 3 fatty acids or analogues: Potential therapeutic benefits. Mini Rev Med Chem. 2004;4(6):659-68. [pmid: 15279600].
Rombouts EK, Rosendaal FR, van der Meer FJ. The effect of vitamin K supplementation on anticoagulant treatment. J Thromb Haemost. Mar. 2006;4(3):691-2. [pmid: 16460460].
Roselle H, Ekatan A, Tzeng J, et al. Symptomatic hepatitis associated with the use of herbal red yeast rice. Ann Intern Med. 2008;149(7):516-7. [pmid: 18838736].
Rowin J, Lewis SL. Spontaneous bilateral subdural hematomas associated with chronic Ginkgo biloba ingestion. Neurology. Jun. 1996;46(6):1775-6. [pmid: 8649594].
Rösel H. Complications and hazards in anticoagulant therapy. [German]. Zentralbl Gynakol. Mar. 28. 1970;92(13):410-5. [pmid: 5513220].
Rubba P. Anti-inflammatory action of statins and reduction of homocysteinemia by vitamin supplementation: interactions among strategies for cardiovascular prevention. Nutrition, metabolism, and cardiovascular diseases. 2000;10(4):173-6.
Rupp H. Omacor (prescription omega-3-acid ethyl esters 90): From severe rhythm disorders to hypertriglyceridemia. Advances in Therapy. 2009;26(7):675-690. Date of Publication: July 2009 2009;(7):675–90. [pmid: 19629408].
Rupp H, Rupp TP, Alter P, et al. N-3 polyunsaturated fatty acids and statins in heart failure. La 1f40 ncet. Jan. 31. 2009;373(9661):378-9. [pmid: 19186263].
Ryan AS, Keske MA, Hoffman JP, et al. Clinical overview of algal-docosahexaenoic acid: effects on triglyceride levels 1f40 and other cardiovascular risk factors. [Review] [54 refs]. Am J Ther. Mar. 2009;16(2):183-92. [pmid: 19145206].
Saito K, Hattori K, Omatsu T, et al. Effects of oral magnesium on blood pressure and red cell sodium transport in patients receiving long-term thiazide diuretics for hypertension. Am J Hypertens. Jul. 1988;1(3 Pt 3):71S-4S. [pmid: 3415812].
Saluk-Juszczak J, Pawlaczyk I, Olas B, et al. The effect of polyphenolic-polysaccharide conjugates from selected medicinal plants of Asteraceae family on the peroxynitrite-induced changes in blood platelet proteins. Int J Biol Macromol. Dec. 1. 2010;47(5):700-5. [pmid: 20869393].
Sanyal S, Kuvin JT, Karas RH. Niacin and laropiprant. [Review] [45 refs]. Drugs Today. Jun. 2010;46(6):371-8. [pmid: 20571606].
Saravanan P, Davidson NC, Schmidt EB, et al. Cardiovascular effects of marine omega-3 fatty acids. The Lancet. 2010;376(9740):540-550. Date of Publication: August 2010 2010;(9740):540–50.
Schaars CF, Stalenhoef AF. Effects of ubiquinone (coenzyme Q10) on myopathy in statin users. [Review] [46 refs]. Curr Opin Lipidol. Dec. 2008;19(6):553-7. [pmid: 18957876].
Schellhorn W. "Calcium gout" with nephrocalcinosis due to long-term dihydrotachysterine therapy. [German]. Med Klin. Aug. 11. 1967;62(32):1232-7. [pmid: 4298777].
Schmidt EB, Dyerberg J. Omega-3 fatty acids. Current status in cardiovascular medicine. [Review] [271 refs]. Drugs. Mar. 1994;47(3):405-24. [pmid: 7514972].
Schneider W, Wehmeier A. Drugs or diet: do they protect against degenerative cardiovascular disease?. [Review] [75 refs]. J Cardiovasc Pharmacol. Suppl 1. 1988;12:S88-96. [pmid: 2468842].
Schoene NW. Vitamin E and omega-3 fatty acids: effectors of platelet responsiveness. [Review] [34 refs]. Nutrition. Oct. 2001;17(10):793-6. [pmid: 11684381].
Scholze A, Tepel M. Hyponatremia. [German]. Med Klin. Feb. 15. 2009;104(2):137-47. [pmid: 19242665].
Schoonover LL. Oxidative stress and the role of antioxidants in cardiovascular risk reduction. [Review] [20 refs]. Prog Cardiovasc Nurs. 2001;16(1):30-2. [pmid: 11252875].
Schumann K. Interactions between drugs and vitamins at advanced age. [Review] [54 refs]. Int J Vitam Nutr Res. May. 1999;69(3):173-8. [pmid: 10389024].
Sconce EA, Kamali F. Appraisal of current vitamin K dosing algorithms for the reversal of over-anticoagulation with warfarin: the need for a more tailored dosing regimen. [Review] [46 refs]. Eur J Haematol. Dec. 2006;77(6):457-62. [pmid: 17042764].
Seelig MS. Interrelationship of magnesium and congestive heart failure. [Review] [112 refs]. Wien Med Wochenschr. 2000;150(15–16):335-41. [pmid: 11105329].
Seiler K, Duckert F. Intoxication with phenprocoumon (marcoumar). Pharmacokinetics and side effects. Thromb Diath Haemorrh. Apr. 30. 1969;21(2):320-4. [pmid: 5769055].
Seppo L, Lähteenmäki T, Tikkanen MJ, et al. Effects of vitamin E on the toxicity of oxidized LDL on endothelial cells in vitro in smokers vs nonsmokers on diets rich in fish. Eur J Clin Nutr. Nov. 2005;59(11):1282-90. [pmid: 16047029].
Shaheen BE, Cornish LA. Magnesium in the treatment of acute myocardial infarction. [Review] [96 refs]. Clin Pharm. Aug. 1993;12(8):588-96. [pmid: 8222523].
Shechter M. Does magnesium have a role in the treatment of patients with coronary artery disease?. [Review] [104 refs]. Am J Cardiovasc Drugs. 2003;3(4):231-9. [pmid: 14728075].
Sherry S. Fibrinolytic agents. [Review] [29 refs]. Dis Mon. May. 1969:3-32. [pmid: 4241828].
Siegel G, Walter A, Engel S, et al. Pleiotropic effects of garlic. [Review] [35 refs] [German]. Wien Med Wochenschr. 1999;149(8–10):217-24. [pmid: 10483684].
Simon HB. Patient-directed, nonprescription approaches to cardiovascular disease. [Review] [230 refs]. Arch Intern Med. Oct. 24. 1994;154(20):2283-96. [pmid: 7944851].
Sinatra ST. Coenzyme Q10: a vital therapeutic nutrient for the heart with special application in congestive heart failure. Conn Med. Nov. 1997;61(11):707-11. [pmid: 9419958].
Sinatra ST. “Care,” cancer and coenzyme Q10. J Am Coll Cardiol. Mar. 1999;33(3):897-9. [pmid: 10080498].
Sinatra ST. Coenzyme Q10 in patients with end-stage heart failure awaiting cardiac transplantation: a randomized, placebo-controlled study. Clin Cardiol. 2004;27(10):A26. [pmid: 15553298].
Sinclair AJ, Murphy KJ, Li D. Marine lipids: overview "news insights and lipid composition of Lyprinol". [Review] [79 refs]. Allerg Immunol (Paris). Sep. 2000;32(7):261-71. [pmid: 11094639].
Singh RB, Singh VP, Jha VK, et al. Magnesium and the heart. Acta Cardiol. 1976;31(5):401-9. [pmid: 1088047].
Singh U, Devaraj S, Jialal I. Coenzyme Q10 supplementation and heart failure. [Review] [54 refs]. Nutr Rev. Jun. 2007;65(6 Pt 1):286-93. [pmid: 17605305].
Skalli S, Zaid A, Soulaymani R. Drug interactions with herbal medicines. [Review] [103 refs]. Ther Drug Monit. Dec. 2007;29(6):679-86. [pmid: 18043467].
Skulas-Ray AC, West SG, Davidson MH, et al. Omega-3 fatty acid concentrates in the treatment of moderate hypertriglyceridemia. Expert Opinion on Pharmacotherapy. 2008;9(7):1237-1248. Date of Publication: May 2008 2008;(7):1237–48. [pmid: 18422480].
Smith GD, Brion MJ, Sterne JA. N-3 polyunsaturated fatty acids and statins in heart failure. La 1f40 ncet. Jan. 31. 2009;373(9661):378-1. [pmid: 19186265].
Smolinske SC. Dietary supplement-drug interactions. [Review] [24 refs]. J Am Med Womens Assoc. 1999;54(4):191-2. [pmid: 10531760].
Smolinske SC. Herbal product contamination and toxicity. Journal of Pharmacy Practice. 2005;18(3):188-208. Date of Publication: Jun 2005 2005;(3):188–208.
Soukoulis V, Dihu JB, Sole M, et al. Micronutrient deficiencies an unmet need in heart failure. [Review] [179 refs]. J Am Coll Cardiol. Oct. 27. 2009;54(18):1660-73. [pmid: 19850206].
Spencer AP, Carson DS, Crouch MA. Vitamin E and coronary artery disease. [Review] [44 refs]. Arch Intern Med. Jun. 28. 1999;159(12):1313-20. [pmid: 10386507].
Spencer DC, Meadows SE, Sontheimer D. Clinical inquiries. In patients with a previous CVA, do antioxidants protect against subsequent stroke?. [Review] [8 refs]. J Fam Pract. Nov. 2002;51(11):976. [pmid: 12485555].
Sperling H, Lümmen G, Luboldt HJ, et al. Secondary erectile dysfunction. Is oral medication in the diagnostic phase indicated?. [German]. Urologe A. Jan. A. 1999;38(1):56-9. [pmid: 10081103].
Spieker C, Zidek W, Vetter H. Calcium antagonists in the treatment of high blood pressure. [German]. Dtsch Med Wochenschr. Dec. 4. 1987;112(49):1908-9. [pmid: 2445537].
Stacpoole PW, Alig J. Advances in the treatment of coronary heart disease: fish oils, cholestyramine, and mevinolin. [Review] [58 refs]. Cardiovasc Clin. 1987;18(1):267-79. [pmid: 3300984].
Stanley WC, Recchia FA, Okere IC. Metabolic therapies for heart disease: Fish for prevention and treatment of cardiac failure?. Cardiovasc Res. 2005;68(2):175-7. [pmid: 16188244].
Stein JH, Carlsson CM, Papcke-Benson K, et al. The effects of lipid-lowering and antioxidant vitamin therapies on flow-mediated vasodilation of the brachial artery in older adults with hypercholesterolemia. J Am Coll Cardiol. Dec. 2001;38(7):1806-13. [pmid: 11738278].
Stein JH, Hadigan CM, Brown TT, et al. Prevention Strategies for Cardiovascular Disease in HIV-infected Patients. Circ Cardiovasc Qual Outcomes. 2008;118(2):e54-e60.
Steinberg D. Is there a potential therapeutic role for vitamin E or other antioxidants in atherosclerosis?. [Review] [43 refs]. Curr Opin Lipidol. Dec. 2000;11(6):603-7. [pmid: 11086333].
Stout CW, Weinstock J, Homoud MK, et al. Herbal medicine: Beneficial effects, side effects, and promising new research in the treatment of arrhythmias. Current Cardiology Reports. 2003;5(5):395-401. Date of Publication: Sep 2003 2003;(5):395–401. [pmid: 12917055].
Tachjian A, Maria V, Jahangir A. Use of herbal products and potential interactions in patients with cardiovascular diseases. [Review] [88 refs]. J Am Coll Cardiol. Feb. 9. 2010;55(6):515-25. [pmid: 20152556].
Tandon VR, Verma S, Singh JB, et al. Antioxidants and cardiovascular health. JK Science. 2005;7(2):111-114. Date of Publication: Apr 2005 2005;(2):111–4.
Tang WHW, Samara MA. Polyunsaturated fatty acids in heart failure: Should we give more and give earlier?. J Am Coll Cardiol. 2011;57(7):880-3. [pmid: 21215549].
Tavazzi L, Tognoni G, Franzosi MG, et al. Rationale and design of the GISSI heart failure trial: a large trial to assess the effects of n-3 polyunsaturated fatty acids and rosuvastatin in symptomatic congestive heart failure. Eur J Heart Fail. Aug. 2004;6(5):635-41. [pmid: 15302013].
Tavintharan S, Kashyap ML. The benefits of niacin in atherosclerosis. [Review] [59 refs]. Curr Atheroscler Rep. Jan. 2001;3(1):74-82. [pmid: 11123852].
Taylor DR, Constable J, Sonnekus M, et al. Effect of indapamide on serum and red cell cations, with and without magnesium supplementation, in subjects with mild hypertension. SAMJ, S. 1988. Sep. 17. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 74(6):273-6. [pmid: 3047887].
Terano T, Hirai A, Shiina T, et al. Mec 300 hanism of anti-proliferative action of eicosapentaenoic acid (EPA) in vascular cell growth: its effect on signal transduction system. [Review] [6 refs]. Adv Exp Med Biol. 1997;407:399-404. [pmid: 9321983].
Tesch BJ. Herbs commonly used by women: An evidence-based review. Am J Obstet Gynecol. 2003;188(5 SUPPL):S44-55. [pmid: 12748451].
Thurnham DI. An overview of interactions between micronutrients and of micronutrients with drugs, genes and immune mechanisms. Nutr. 2004;17(2):211-40.
Tolman KG. Defining patient risks from expanded preventive therapies. [Review] [22 refs]. Am J Cardiol. Jun. 22. 2000;85(12A):15E-9E. [pmid: 10858489].
Touyz RM. Role of magnesium in the pathogenesis of hypertension. Molecular Aspects of Medicine. 2003;24(1–3):107-136. Date of Publication: 06 Feb 2003 2003;(1–3):107–36. [pmid: 12537992].
Tziomalos K, Athyros VG, Mikhailidis DP. Fish oils and vascular disease prevention: an update. [Review] [103 refs]. Curr Med Chem. 2007;14(24):2622-8. [pmid: 17979714].
Ude M, Hengstler S, Schulz M, et al. Mineral nutrients and trace elements - a case for consultation. [German]. Pharmazie in Unserer Zeit. 2009;38(3):268-276. Date of Publication: May 2009 2009;(3):268–76. [pmid: 19396919].
Valli G, Giardina EG. Benefits, adverse effects and drug interactions of herbal therapies with cardiovascular effects. Journal of the American College of Cardiology. 2002;39(7):1083-1095. Date of Publication: 03 Apr 2002 2002;(7):1083–95. [pmid: 11923030].
van Doormaal JJ, Idema IG, Muskiet FA, et al. Effects of short-term high dose intake of evening primrose oil on plasma and cellular fatty acid compositions, alpha-tocopherol levels, and erythropoiesis in normal and type 1 (insulin-dependent) diabetic men. Diabe 1f40 tologia. Aug. 1988;31(8):576-84. [pmid: 3065111].
Vannacci A, Lapi F, Gallo E, et al. Red yeast rice for dyslipidemia in statin-intolerant patients. Ann Intern Med. Jan. 2010;152(2):135-6. [pmid: 20083842].
Vaturi M, Strasberg B. Magnesium in the management of acute myocardial infarction--has it proved beneficial?. [Review] [9 refs]. Int J Cardiol. Dec. 1. 1999;71(3):217-8. [pmid: 10636526].
Vermani M, Milosevic I, Smith F, et al. Herbs for mental illness: Effectiveness and interaction with conventional medicines. J Fam Pract. 2005;54(9):789-800. [pmid: 16144593].
Violi F, Micheletta F, Iuliano L. Clinical trials with vitamin E in cardiovascular disease: are they meaningful?. Thromb Haemost. Oct. 2001;86(4):1121-2. [pmid: 11686337].
Vo AN, Kashyap ML. Fixed-dose combination of extended-release niacin plus simvastatin for lipid disorders. [Review] [58 refs]. Expert Rev Cardiovasc Ther. Nov. 2008;6(10):1303-10. [pmid: 19018682].
Vogt A, Kassner U, Hostalek U, et al. Correction of low HDL cholesterol to reduce cardiovascular risk: practical considerations relating to the therapeutic use of prolonged-release nicotinic acid (Niaspan). [Review] [67 refs]. Int J Clin Pract. Nov. 2007;61(11):1914-21. [pmid: 17935550].
von SC. Prophylaxis of atherosclerosis with marine omega-3 fatty acids. A comprehensive strategy. [Review] [173 refs]. Ann Intern Med. Dec. 1987;107(6):890-9. [pmid: 2825573].
von SC. Cardiovascular disease prevention and treatment. [Review] [54 refs]. Prostaglandins Leukot Essent Fatty Acids. Aug. 2009;81(2–3):193-8. [pmid: 19520557].
Walenga JM, Adiguzel C. Drug and dietary interactions of the new and emerging oral anticoagulants. Int J Clin Pract. Jun. 2010;64(7):956-67. [pmid: 20584229].
Wali VB, Bachawal SV, Sylvester PW. Combined treatment of gamma-tocotrienol with statins induce mammary tumor cell cycle arrest in G1. Exp Biol Med (Maywood). Jun. 2009;234(6):639-50. [pmid: 19359655].
Walker WG. Indications and contraindications for diuretic therapy. Ann New York Acad Sci. Nov. 22. 1966;139(2):481-96. [pmid: 5230289].
Warkentin TE. Should vitamin K be administered when HIT is diagnosed after administration of coumarin?. J Thromb Haemost. Apr. 2006;4(4):894-6. [pmid: 16634761].
Warnholtz A, Mollnau H, Oelze M, et al. Antioxidants and endothelial dysfunction in hyperlipidemia. [Review] [62 refs]. Curr Hypertens Rep. Feb. 2001;3(1):53-60. [pmid: 11177709].
Watson M, Roulston A, Bélec L, et al. The small molecule GMX1778 is a potent inhibitor of NAD+ biosynthesis: strategy for enhanced therapy in nicotinic acid phosphoribosyltransferase 1-deficient tumors. Mol Cell Biol. Nov. 2009;29(21):5872-88. [pmid: 19703994].
Watson RR. Nutraceutical synergism: Pycnogenol and coenzyme Q_10_ enhance cardiovascular health. Evidence-Based Integrative Medicine. 2005;2(2):67-70. Date of Publication: 2005 2005;(2):67–70.
Weihmayr T, Ernst E. Therapeutic effectiveness of Crataegus. Fortschr Med Orig. 1996;114(1–2):27-9.
Weir MR. Is activated vitamin D supplementation renoprotective?. Hypertension. Aug. 2008;52(2):211-2. [pmid: 18606899].
Weissmann G. Aspirin. Sci Am. Jan. 1991;264(1):84-90. [pmid: 1899486].
Werneke U. Risk management of nutritional supplements in chronic illness: The implications for the care of cancer and depression. Proceedings of the Nutrition Society. 2007;66(4):483-492. Date of Publication: Nov 2007 2007;(4):483–92. [pmid: 17961269].
West AL, Oren GA, Moroi SE. Evidence for the use of nutritional supplements and herbal medicines in common eye diseases. Am J Ophthalmol. 2006;141(1):157-66. [pmid: 16386992].
Wester PO, Dyckner T. Magnesium and hypertension. [Review] [71 refs]. J Am Coll Nutr. Aug. 1987;6(4):321-8. [pmid: 3301983].
Whayne TF Jr. High-density lipoprotein cholesterol: current perspective for clinicians. [Review] [44 refs]. Angiology. Oct. 2009;60(5):644-9. [pmid: 19240106].
Wijewickrama ES, Hewage UC, Jayaratne SD. Iatrogenic hypocalcaemia following magnesium sulphate therapy in a patient with tetanus. Ceylon Med J. Dec. 2004;49(4):132. [pmid: 15693453].
Willgeroth F, Rummel W. Drugs in pregnancy and lactation (ending). [German]. Fortschr Med Orig. Dec. 20. 1979;97(48):2226-34. [pmid: 535871].
Williamson EM. Drug interactions between herbal and prescription medicines. [Review] [100 refs]. Drug Saf. 2003;26(15):1075-92. [pmid: 14640772].
Witkowski JA, Parish LC. The other medicine: Complementary and alternative - Why, why not?. Clinics in Dermatology. 2002;20(4):456-460. Date of Publication: Jul 2002 2002;(4):456–60. [pmid: 12208636].
Wittkowsky AK. Drug interactions update: drugs, herbs, and oral anticoagulation. [Review] [22 refs]. J Thromb Thrombolysis. Sep. 2001;12(1):67-71. [pmid: 11711691].
Wittkowsky AK, Bussey HI, Walker MB, et al. Dietary supplement use among anticoagulation clinic patients [8]. Journal of Thrombosis and Haemostasis. 2007;5(4):875-877. Date of Publication: Apr 2007 2007;(4):875–7. [pmid: 17229055].
Wittkowsky AK. Dietary supplements and oral anticoagulants. Clinical Advances in Hematology & Oncology. Jun. 2010;8(6):399-400. [pmid: 20733548].
Wolff G. Hypoglycemia. 3. [Review] [72 refs] [German]. Med Monatsschr. Jul. 1970;24(7):297-300. [pmid: 4104398].
Wolfram G. Dietary fatty acids and coronary heart disease. [Review] [28 refs]. Eur J Med Res. Aug. 20. 2003;8(8):321-4. [pmid: 12915326].
Wolfram G. N-3 fatty acids have a preventive effect. [German]. Ernahrungs Umschau. 2006;53(5):174-5.
Wong GK, Poon WW. Re: Magnesium sulfate: role as possible attenuating factor in vasospasm morbidity (Prevedello DM et al. Surg Neurol 2006;65:S1:14-S1:21). Surg Neurol. Jul. 2006;66(1):110-1. [pmid: 16793465].
Wynn RL. The effects of CoQ10 supplements on patients taking statin drugs. Gen Dent. May. 2010;58(3):168-70. [pmid: 20478794].
Yetiv JZ. Clinical applications of fish oils. [Review] [119 refs]. J Am Med Assoc. Aug. 5. 1988;260(5):665-70. [pmid: 3292794].
Yilmaz MB, Yontar OC, Turgut OO, et al. Herbals in cardiovascular practice: are physicians neglecting anything?. Int J Cardiol. Oct. 31. 2007;122(1):48-51. [pmid: 17182136].
Yokoyama M, Origasa H. Effects of eicosapentaenoic acid on cardiovascular events in Japanese patients with hypercholesterolemia: rationale, design, and baseline characteristics of the Japan EPA. Lipid Intervention Study (JELIS). Am Heart J. Oct. 2003;146(4):613-20. [pmid: 14564313].
Young HY, Liao JC, Chang YS, et al. Synergistic effect of ginger and nifedipine on human platelet aggregation: a study in hypertensive patients and normal volunteers. Am J Chin Med. 2006;34(4):545-51. [pmid: 16883626].
Yovchevski PH, Doncheva NI. Low-dose statin concentration in red yeast rice: a confounding effect on outcome?. [Erratum appears in Mayo Clin Proc. 2008 Nov;83(11):1301]. Mayo Clin Proc. Oct. 2008;83(10):1187. [pmid: 18828982].
Zellner C, Boyle A, Yeghiazarians Y. Magnesium sulfate for transradial cardiac catheterization: teaching an old dog new tricks. J Invasive Cardiol. Oct. 2008;20(10):543-4. [pmid: 18829999].
Zeman M, Zá kA, et al. N-3 fatty acid supplementation decreases plasma homocysteine in diabetic dyslipidemia treated with statin-fibrate combination. J nutr biochem. Jun. 2006;17(6):379-84. [pmid: 16214329].
Zhou YM, Huang ZQ, Hu MH, et al. Clinical study on the effect of Shengxueling on idiopathic thrombocytopenic purpura. Chin J Integr Med. Mar. 2005;11(1):60-4. [pmid: 15975312].
Zumkley H, Wessels F, Winter R, et al. Magnesia intoxication in insufficiency of the kidney (author’s transl). [German]. Med Klin. Apr. 5. 1974;69(14):587-92. [pmid: 4838936].

## Not Relevant Systematic Review

Eligibility: Systematic review on dietary supplements meeting minimum criteria for inclusion

Ang-Lee MK, Moss J, Yuan CS. Herbal medicines and perioperative care. [Review] [122 refs]. J Am Med Assoc. Jul. 11. 2001;286(2):208-16. [pmid: 11448284].
Backes JM, Gibson CA, Howard PA. Optimal lipid modification: the rationale for combination therapy. [Review] [141 refs]. Vasc Health Risk Manag. 2005;1(4):317-31. [pmid: 17315604].
Birjmohun RS, Hutten BA, Kastelein JJ, et al. Efficacy and safety of high-density lipoprotein cholesterol-increasing compounds: a meta-analysis of randomized controlled trials. J Am Coll Cardiol. Jan. 18. 2005;45(2):185-97. [pmid: 15653014].
Chagan L, Ioselovich A, Asherova L, et al. Use of alternative pharmacotherapy in management of cardiovascular diseases. [Review] [106 refs]. Am J Manag Care. Mar. 2002;8(3):270-85. [pmid: 11924555].
Coon JT, Ernst E. Panax ginseng: a systematic review of adverse effects and drug interactions. [Review] [193 refs]. Drug Saf. 2002;25(5):323-44. [pmid: 12020172].
Daniele C, Mazzanti G, Pittler MH, et al. Adverse-event profile of Crataegus spp.: a systematic review. [Review] [41 refs]. Drug Saf. 2006;29(6):523-35. [pmid: 16752934].
Dentali F, Ageno W. Management of coumarin-associated coagulopathy in the non-bleeding patient: a systematic review. [Review] [27 refs]. Haematologica. Jul. 2004;89(7):857-62. [pmid: 15257939].
Desai D, Hasan A, Wesley R, et al. Effects of dietary supplements on aspirin and other antiplatelet agents: An evidence-based approach. Thromb Res. 2005;117(1–2):87-101. [pmid: 16115664].
Ernst E. The risk-benefit profile of commonly used herbal therapies: Ginkgo, St. John’s Wort, Ginseng, Echinacea, Saw Palmetto, and Kava. [Review] [76 refs][Erratum appears in Ann Intern Med 2003 Jan 7; 138(1):79]. Ann Intern Med. Jan. 1. 2002;136(1):42-53. [pmid: 11777363].
Ernst E. Serious psychiatric and neurological adverse effects of herbal medicines - A systematic review. Acta Psychiatr Scand. 2003;108(2):83-91. [pmid: 12823164].
Ernst E. Cardiovascular adverse effects of herbal medicines: A systematic review of the recent litarature. Can J Cardiol. 2003;19(7):818-27. [pmid: 12813616].
Fugh-Berman A, Ernst E. Herb-drug interactions: review and assessment of report reliability. [Review] [71 refs][Erratum appears in Br J Clin Pharmacol 2002 Apr;53(4):449P]. Br J Clin Pharmacol. Nov. 2001;52(5):587-95. [pmid: 11736868].
Gold JL, Laxer DA, Dergal JM, et al. Herbal-drug therapy interactions: A focus on dementia. Curr Opin Clin Nutr Metab Care. 2001;4(1):29-34. [pmid: 11122556].
Hamer M, Steptoe A. Influence of specific nutrients on progression of atherosclerosis, vascular function, haemostasis and inflammation in coronary heart disease patients: A systematic review. Br J Nutr. 2006;95(5):849-59. [pmid: 16611374].
He SM, Li CG, Liu JP, et al. Disposition pathways and pharmacokinetics of herbal medicines in humans. Curr Med Chem. 2010;17(33):4072-113. [pmid: 20939821].
Huntley AL, Coon JT, Ernst E. The safety of herbal medicinal products derived from Echinacea species: A systematic review. Drug Saf. 2005;28(5):387-400. [pmid: 15853441].
Izzo AA, Ernst E. Interactions between herbal medicines and prescribed drugs: a systematic review (DARE structured abstract). Drugs. 2001;61:2163-75. [pmid: 11772128].
Javed F, Golagani A, Sharp H. Potential effects of herbal medicines and nutritional supplements on coagulation in ENT practice. [Review] [28 refs]. J Laryngol Otol. Feb. 2008;122(2):116-9. [pmid: 17640426].
Kennedy DA, Seely D. Clinically based evidence of drugherb interactions: A systematic review. Expert Opin Drug Saf. 2010;9(1):79-124. [pmid: 20021292].
Levy HB, Kohlhaas HK. Considerations for supplementing with coenzyme Q10 during statin therapy. [Review] [33 refs]. Ann Pharmacother. Feb. 2006;40(2):290-4. [pmid: 16449543].
Makris GC, Geroulakos G, Makris MC, et al. The pleiotropic effects of statins and omega-3 fatty acids against sepsis: a new perspective. [Review] [67 refs]. Expert Opin Investig Drugs. Jul. 2010;19(7):809-14. [pmid: 20470189].
Marino J, Motz D, Shields K. Warfarin and supplement interactions: Survey of published literature. Journal of Pharmacy Technology. 2011;27(2):63-70.
Melzer J, Saller R. Hawthorn (Crataegus) in Heart Failure: A review. Schweiz Z Ganzheits Medizin. Oct. 2005;17(6):362-6.
Mills E, Wu P, Johnston BC, et al. Natural health product-drug interactions: A systematic review of clinical trials. Ther Drug Monit. 2005;27(5):549-57. [pmid: 16175124].
Reiner Z. Combined therapy in the treatment of dyslipidemia. [Review] [106 refs]. Fundam Clin Pharmacol. Feb. 2010;24(1):19-28. [pmid: 19682080].
Rosenfeldt F, Hilton D, Pepe S, et al. Systematic review of effect of coenzyme Q10 in physical exercise, hypertension and heart failure. [Review] [29 refs]. Biofactors. 2003;18(1–4):91-100. [pmid: 14695924].
Sander S, Coleman CI, Patel AA, et al. The impact of coenzyme Q10 on systolic function in patients with chronic heart failure. J Card Fail. Aug. 2006;12(6):464-72. [pmid: 16911914].
Shekelle P, Morton S, Hardy ML. Effect of supplemental antioxidants vitamin C, vitamin E, and coenzyme Q10 for the prevention and treatment of cardiovascular disease. Evidence report/technology assessment (Summary). 2003;(83):1-3. Date of Publication: Jun 2003 2003;(Summary):1–3.
Simons S, Wollersheim H, Thien T. A systematic review on the influence of trial quality on the effect of garlic on blood pressure. [Review] [51 refs]. Neth J Med. Jun. 2009;67(6):212-9. [pmid: 19749390].
Soja AM, Mortensen SA. Treatment of congestive heart failure with coenzyme Q10 illuminated by meta-analyses of clinical trials. Mol Aspects Med. Suppl. 1997;18:S159-168. [pmid: 9266518].
Tran MT, Mitchell TM, Kennedy DT, et al. Role of coenzyme Q10 in chronic heart failure, angina, and hypertension. [Review] [60 refs]. Pharmacotherapy. Jul. 2001;21(7):797-806. [pmid: 11444576].
Vaes LP, Chyka PA. Interactions of warfarin with garlic, ginger, ginkgo, or ginseng: nature of the evidence. [Review] [46 refs]. Ann Pharmacother. Dec. 2000;34(12):1478-82. [pmid: 11144706].
Wang C, Chung M, Lichtenstein A, et al. Effects of omega-3 fatty acids on cardiovascular disease. Evid Rep Technol Assess (Summ). Mar. 2004;(94):1-8. [pmid: 15133888].
Wells PS, Holbrook AM, Crowther NR, et al. Interactions of warfarin with drugs and food. [Review] [153 refs]. Ann Intern Med. Nov. 1. 1994;121(9):676-83. [pmid: 7944078].
Wittkowsky AK. A systematic review and inventory of supplement effects on warfarin and other anticoagulants. Thromb Res. 2005;117(1–2):81-6. [pmid: 15921725].
Yang XX, Hu ZP, Duan W, et al. Drug-herb interactions: eliminating toxicity with hard drug design. [Review] [172 refs]. Curr Pharm Des. 2006;12(35):4649-64. [pmid: 17168768].
Yasaka M, Minematsu K, Naritomi H, et al. Predisposing factors for enlargement of intracerebral hemorrhage in patients treated with warfarin. [Review] [18 refs]. Thromb Haemost. Feb. 2003;89(2):278-83. [pmid: 12574807].
Yim BT, Chong PH. Niacin-ER and lovastatin treatment of hypercholesterolemia and mixed dyslipidemia. [Review] [56 refs]. Ann Pharmacother. Jan. 2003;37(1):106-15. [pmid: 12503944].
Zhou SF, Zhou ZW, Li CG, et al. Identification of drugs that interact with herbs in drug development. [Review] [111 refs]. Drug Discov Today. Aug. 2007;12(15–16):664-73. [pmid: 17706549].

## Not Relevant Language

Eligibility: English systematic review OR English/German primary study

Balli E, Giomi A, Del CF. Magnesium sulfate in acute myocardial infarction. [Review] [33 refs] [Italian]. G Ital Cardiol. Nov. 1995;25(11):1425-32. [pmid: 8682239].
Bertler A, Redfors A. Arrhythmias. 3. Digitalis induced arrhythmia. [Swedish]. Lakartidningen. Jun. 14. 1971;68(Suppl). [pmid: 4398812].
Campanacci D. Current data on the physiopathological and therapeutic importance of vitamin C. [Italian]. G Clin Med. Jan. 1974;55(1):1-4. [pmid: 4409096].
Chernomorets NN, Kotlubeĭ GV, et al. The effect of tocopherol and nicotinic acid on the microcirculation and blood coagulability in patients with ischemic heart disease. [Russian]. Vrach Delo. Dec. 1990;(12):6-8. [pmid: 2089804].
Denisiuk VI. Effect of antibradykinin preparations and nicotinic acid on the microcirculation and blood oxygen balance of ischemic heart disease patients in the initial stage of heart failure. [Russian]. Kardiologiia. Aug. 1983;23(8):103-5. [pmid: 6620828].
Iwamoto M, Sato T, Ishizaki T. The clinical effect of Crataegutt in heart disease of ischemic or hypertensive origin. A multicenter double-blind study. [German]. Planta Med. May. 1981;42(1):1-16. [pmid: 7019949].
Kanorski S, Drikova VV, Kanorskaia I. Influence of perindopril, rosuvastatin, or omega-3 polyunsaturated fatty acids on efficacy of antirecurrence therapy with sotalol in patients with persistent atrial fibrillation. [Russian]. Kardiologiia. 2007;47(12):39-44. [pmid: 18260977].
Kim JS, Lee SH, Kim JM, et al. Studies on the efficacy and safety of Ginkgo biloba extract (Tanaminregistered trade mark) in the dizziness of central origin. Journal of Korean Society for Clinical Pharmacology and Therapeutics. 1995;3(2):187-95.
Kraft K. Phytotherapy. Which drugs and drug preparations show high evidence?. Tagl Prax. 2006;47(3):657-64.
Li B, Zhu W-L, Chen K-X. Advances in the study of berberine and its derivatives. Yaoxue Xuebao. 2008;43(8):773-87.
Malm OJ. Contribution of magnesium in long-term diuretic treatment? Magnesium deficiency. [Norwegian]. Tidsskr Nor Laegeforen. Feb. 20. 1977;97(5):253-4. [pmid: 841562].
Martynov AI, Stepura OB, Shekhter AB, et al. New approaches to the treatment of patients with idiopathic mitral valve prolapse. [Russian]. Ter Arkh. 2000;72(9):67-70. [pmid: 11076423].
Mazurets AF, Gurevich MA, Kubyshkin VF, et al. Coenzyme metabolic therapy in infectious allergic myocarditis. [Russian]. Klin Med (Mosk). 1995;73(5):41-3. [pmid: 8815275].
Pogozheva AV, Samsonov MA, Levachev MM. Clinico-biochemical validation of the use of PUFA omega-3 in patients with ischemic heart disease, familial hyperlipoproteinemias and hypertension. [Russian]. Vopr Pitan. 1996;(1):34-6. [pmid: 9157710].
Rogowski W, Kasprzak JD. Electrolyte balance abnormalities and potassium supplementation in patients with cardiovascular diasease. Polski Przeglad Kardiologiczny. 2002;4(1):57-60.
Rosero Arenas MA, Rosero AE, Portaceli A, et al. Usefulness of phyto-oestrogens in reduction of blood pressure. Systematic review and meta-analysis. [Review] [74 refs] [Spanish]. Aten Primaria. Apr. 2008;40(4):177-86. [pmid: 18405582].
Rumiantseva OI, Pogozheva AV, Pokrovskaia GR, et al. Correction of mineral metabolism impairment with an allowance for seasonal fluctuations in patients with ischemic heart disease and hypertensive disease with overweight. [Russian]. Vopr Pitan. 2001;70(2):25-8. [pmid: 11494667].
Samsonov MA, Pogozheva AV. Marine fish oil in the prevention and treatment of cardiovascular diseases. [Russian]. Vestn Ross Akad Med Nauk. 1996;(12):43-9. [pmid: 9102080].
Schneider B. Ginkgo biloba extract in peripheral arterial diseases. Meta-analysis of controlled clinical studies. [German]. Arzneimittelforschung. Apr. 1992;42(4):428-36. [pmid: 1386514].
Solhaug V, Nergård CS. Interactions between warfarin and natural products. [Norwegian]. Tidsskr Nor Laegeforen. Jun. 17. 2010;130(12):1252-4. [pmid: 20567279].
Vizir AD, Dunaev VV, Berezin AE, et al. The optimization of the hemodynamic characteristics in patients with ischemic heart disease and circulatory failure by using a substrate-coenzyme complex. [Russian]. Lik Sprava. Sep. 1997;(5):53-6. [pmid: 9491697].
Wirth A, Middelhoff G, Braeuning C, et al. Treatment of familial hypercholesterolemia with a combination of bezafibrate and guar. Atherosclerosis. Dec. 1982;45(3):291-7. [pmid: 7159500].