# Evidence Tables

The purpose of Appendix C is to provide detailed evidence tables that depict the criteria used to determine validity for each study and show the risk of bias assessment made to each study. Furthermore, the tables summarize the evidence described and reflect specific information discussed in the report. The tables are categorized and alphabetized. The categories are: General Characteristics; Interventions; Outcomes by Key Question and outcome; Risk of Bias.

Evidence Table 57 General characteristics of all studies

Evidence Table 58 Interventions listed in detail for all studies

## Outcomes Tables Categorized by Key Question and Outcome

Evidence Table 59 KQ1—Dichotomous data—Mortality

Evidence Table 60 KQ1—Dichotomous data—Ischemic heart disease (coronary artery disease)

Evidence Table 61 KQ1—Dichotomous data—Composite cardiovascular outcome

Evidence Table 62 KQ1—Dichotomous data—Arrhythmia

Evidence Table 63 KQ1—Dichotomous data—Other heart disease

Evidence Table 64 KQ1 - Dichotomous data—Cerebrovascular disease

Evidence Table 65 KQ1—Dichotomous data—Peripheral arterial disease

Evidence Table 66 KQ1—Dichotomous data—CVD surgery and procedures

Evidence Table 67 KQ1—Dichotomous data—Hospitalization

Evidence Table 68 KQ1—Dichotomous data—Adherence to cardiovascular drug

Evidence Table 69 KQ1—Continuous data—Ischemic heart disease (coronary artery disease)

Evidence Table 70 KQ1—Continuous data—Cerebrovascular disease

Evidence Table 71 KQ1—Continuous data—Quality of life

Evidence Table 72 KQ2—Continuous data—Bleeding time

Evidence Table 73 KQ2—Continuous data—Clotting time

Evidence Table 74 KQ2—Continuous data—Coronary artery calcification

Evidence Table 75 KQ2—Continuous data—C-reactive protein

Evidence Table 76 KQ2—Continuous data—Diastolic blood pressure (DBP)

Evidence Table 77 KQ2—Continuous data—High-density lipoprotein cholesterol (HDL-C)

Evidence Table 78 KQ2—Continuous data—INR

Evidence Table 79 KQ2—Continuous data—Low-density lipoprotein cholesterol (LDL-C)

Evidence Table 80 KQ2—Continuous data—Non-HDL-C

Evidence Table 81 KQ2—Continuous data—Platelet aggregability

Evidence Table 82 KQ2—Continuous data—Platelet count

Evidence Table 83 KQ2—Continuous data—Prothrombin time (PT)

Evidence Table 84 KQ2—Continuous data—Proteinuria

Evidence Table 85 KQ2—Continuous data—Systolic blood pressure (SBP)

Evidence Table 86 KQ2—Continuous data—TD: HDL-C

Evidence Table 87 KQ2—Continuous data—Total cholesterol

Evidence Table 88 KQ2—Continuous data—Triglycerides

Evidence Table 89 KQ2—Continuous data—Activated partial thromboplastin time (aPTT)

Evidence Table 90 KQ2—Continuous data—Ejection fraction

Evidence Table 91 KQ2—Continuous data—Lipoprotein A

Evidence Table 92 KQ2—Continuous data—PR interval

Evidence Table 93 KQ2—Dichotomous outcomes

Evidence Table 94 KQ3—Continuous Alanine transaminase (ALT)

Evidence Table 95 KQ3—Continuous—Alkaline phosphatase

Evidence Table 96 KQ 3—Continuous Anemia: Other parameter (e.g. ferritin, MCV, MCH). Specify outcome—Hemoglobin

Evidence Table 97 KQ 3—Continuous Aspartate aminotransferase (AST)

Evidence Table 98 KQ 3—Continuous Blood urea nitrogen (BUN)

Evidence Table 99 KQ 3—Continuous CK or CPK

Evidence Table 100 KQ 3—Continuous Creatinine

Evidence Table 101 KQ 3—Continuous Fasting blood glucose

Evidence Table 102 KQ 3—Continuous Fasting plasma glucose

Evidence Table 103 KQ 3—Continuous Glomeluar filtration rate

Evidence Table 104 KQ 3—Continuous Glycosylated hemoglobin (HbA1c)

Evidence Table 105 KQ 3—Continuous Hematocrit

Evidence Table 106 KQ 3 Continuous Leukopenia: WBC count

Evidence Table 107 KQ 3—Continuous Myalgia

Evidence Table 108 KQ 3—Continuous Myoglobin

Evidence Table 109 KQ 3—Continuous QT interval

Evidence Table 110 KQ 3—Continuous RBC count

Evidence Table 111 KQ 3—Continuous Serum potassium

Evidence Table 112 KQ3—Dichotomous outcomes—Abnormal ECG

Evidence Table 113 KQ3—Dichotomous outcomes—Adverse event other (other than neurologic, allergic, gastrointestinal, bleeding, withdrawal due to adverse event)

Evidence Table 114 KQ3—Dichotomous outcomes—Adverse events general

Evidence Table 115 KQ3—Dichotomous—Alanine transaminase (ALT) (raised)

Evidence Table 116 KQ3- Dichotomous – Alkaline phosphatase

Evidence Table 117 KQ3—Dichotomous—Anemia

Evidence Table 118 KQ3—Dichotomous—Any adverse event

Evidence Table 119 KQ3—Dichotomous—Asparatate aminotransaminase (AST) raised

Evidence Table 120 KQ3—Dichotomous—Asparatate aminotransferase (AST) raised

Evidence Table 121 KQ3—Dichotomous—Bleeding

Evidence Table 122 KQ3—Dichotomous—Bloating

Evidence Table 123 KQ3—Dichotomous—Blood urea nitrogen (BUN) (raised)

Evidence Table 124 KQ3—Dichotomous—Parallel—CK or CPK

Evidence Table 125 KQ3—Dichotomous—Constipation

Evidence Table 126 KQ3—Dichotomous—Creatinine (raised)

Evidence Table 127 KQ3—Dichotomous—Parallel—Diarrhea

Evidence Table 128 KQ3—Dichotomous—Dizziness

Evidence Table 129 KQ3—Dichotomous—Fasting blood glucose

Evidence Table 130 KQ3-Dichotomous—Fishy taste

Evidence Table 131 KQ3—Dichotomous—Flatulence

Evidence Table 132 KQ3—Dichotomous—Flushing

Evidence Table 133 KQ3—Dichotomous—Gastrointestinal adverse events

Evidence Table 134 KQ3—Dichotomous—Generalized edema

Evidence Table 135 KQ3—Dichotomous—Glomerular filtration rate (GFR)

Evidence Table 136 KQ3—Dichotomous—Headache

Evidence Table 137 KQ3—Dichotomous—Hematuria

Evidence Table 138 KQ3—Dichotomous—Hyperglycemia

Evidence Table 139 KQ3—Dichotomous—Hypoglycemia

Evidence Table 140 KQ3—Dichotomous—Hyperkalaemia

Evidence Table 141 KQ3—Dichotomous—Hypokalaemia

Evidence Table 142 KQ3—Dichotomous—Indigestion

Evidence Table 143 KQ3—Dichotomous—Infection

Evidence Table 144 KQ3—Dichotomous—INR

Evidence Table 145 KQ3—Dichotomous—INR > 3.5

Evidence Table 146 KQ3—Dichotomous—Insomnia

Evidence Table 147 KQ3—Dichotomous outcomes—Leukopenia

Evidence Table 148 KQ3—Dichotomous outcomes—Major bleeding

Evidence Table 149 KQ3—Dichotomous outcomes—Myalgia

Evidence Table 150 KQ3—Dichotomous—Nausea

Evidence Table 151 KQ3—Dichotomous—Other adverse events

Evidence Table 152 KQ3—Dichotomous—Prothrombin time (above/below threshold)

Evidence Table 153 KQ3—Dichotomous—Serious adverse events (composite outcome)

Evidence Table 154 KQ3—Dichotomous—Sinusitis

Evidence Table 155 KQ3—Dichotomous—Thrombocytopenia

Evidence Table 156 KQ3—Dichotomous—Total adverse events

Evidence Table 157 KQ3—Dichotomous—Upper respiratory infection

Evidence Table 158 KQ3—Dichotomous—Vomiting

Evidence Table 159 KQ3—Dichotomous—Withdrawal due to adverse events

Evidence Table 160 KQ4—Continuous data—Absorption

Evidence Table 161 KQ4—Cmax

Evidence Table 162 KQ4—Tmax (hours)

Evidence Table 163 KQ4—Continuous data—Distribution

Evidence Table 164 KQ4—Continuous data—Clearance

Evidence Table 165 KQ4 Outcomes—Elimination rate

Evidence Table 166 KQ4 Outcomes—Half life (T1/2)

Evidence Table 167 KQ4—Continuous data—Area under the curve (AUC)

Evidence Table 168 Risk of bias assessment for all studies

## References

1 Abdul MI, Jiang X, Williams KM, et al. Pharmacokinetic and pharmacodynamic interactions of echinacea and policosanol with warfarin in healthy subjects. Br J Clin Pharmacol. May. 2010;69(5):508-15. [pmid: 20573086].
2 Aruna D, Naidu MU. Pharmacodynamic interaction studies of Ginkgo biloba with cilostazol and clopidogrel in healthy human subjects. Br J Clin Pharmacol. Mar. 2007;63(3):333-8. [pmid: 17010102].
3 Avogaro P, Capri C, Cazzolato G, et al. Effects of the combination of nicotinic acid and propranolol in very low doses on blood lipids in man. Atherosclerosis. Sep. 1974;20(2):395-400. [pmid: 4369975].
4 Balestrieri GP, Maffi V, Sleiman I, et al. Fish oil supplementation in patients with heterozygous familial hypercholesterolemia. Recenti Prog Med. Mar. 1996;87(3):102-5. [pmid: 8650428].
5 Barbagallo M, Dominguez LJ, Tagliamonte MR, et al. Effects of vitamin E and glutathione on glucose metabolism: role of magnesium. Hypertension. Oct. 1999;34(4 Pt 2):1002-6. [pmid: 10523398].
6 Bargossi AM, Grossi G, Fiorella PL, et al. Exogenous CoQ10 supplementation prevents plasma ubiquinone reduction induced by HMG-CoA reductase inhibitors. Mol Aspects Med. Suppl. 1994;15:s187-s193. [pmid: 7752830].
7 Bashir Y, Sneddon JF, Staunton HA, et al. Effects of long-term oral magnesium chloride replacement in congestive heart failure secondary to coronary artery disease. Am J Cardiol. Nov. 15. 1993;72(15):1156-62. [pmid: 8237806].
8 Bays HE, McKenney J, Maki KC, et al. Effects of prescription omega-3-acid ethyl esters on non--high-density lipoprotein cholesterol when coadministered with escalating doses of atorvastatin. Mayo Clin Proc. Feb. 2010;85(2):122-8. [pmid: 20118387].
9 Bays HE, Maki KC, Doyle RT, et al. The effect of prescription omega-3 fatty acids on body weight after 8 to 16 weeks of treatment for very high triglyceride levels. Postgrad Med. Sep. 2009;121(5):145-50. [pmid: 19820283].
10 Bender NK, Kraynak MA, Chiquette E, et al. Effects of marine fish oils on the anticoagulation status of patients receiving chronic warfarin therapy. J Thromb Thrombolysis. 1998;5(3):257-61. [pmid: 10767122].
11 Bordia A, Verma SK, Srivastava KC. Effect of garlic (Allium sativum) on blood lipids, blood sugar, fibrinogen and fibrinolytic activity in patients with coronary artery disease. Prostaglandins Leukot Essent Fatty Acids. Apr. 1998;58(4):257-63. [pmid: 9654398].
12 Budoff MJ, Takasu J, Flores FR, et al. Inhibiting progression of coronary calcification using Aged Garlic Extract in patients receiving statin therapy: a preliminary study. Prev Med. Nov. 2004;39(5):985-91. [pmid: 15475033].
13 Caso G, Kelly P, McNurlan MA, et al. Effect of coenzyme q10 on myopathic symptoms in patients treated with statins. Am J Cardiol. May. 15. 2007;99(10):1409-12. [pmid: 17493470].
14 Chan DC, Watts GF, Mori TA, et al. Factorial study of the effects of atorvastatin and fish oil on dyslipidaemia in visceral obesity. Eur J Clin Invest. Jun. 2002;32(6):429-36. [pmid: 12059988].
15 d'Arcangues C, Piaggio G, Brache V, et al. Effectiveness and acceptability of vitamin E and low-dose aspirin, alone or in combination, on Norplant-induced prolonged bleeding. Contraception. Dec. 2004;70(6):451-62. [pmid: 15541406].
16 Davidson MH, Stein EA, Bays HE, et al. Efficacy and tolerability of adding prescription omega-3 fatty acids 4 g/d to simvastatin 40 mg/d in hypertriglyceridemic patients: an 8-week, randomized, double-blind, placebo-controlled study. Clin Ther. Jul. 2007;29(7):1354-67. [pmid: 17825687].
17 Davidson MH, Macariola-Coad JR, McDonald AM, et al. Separate and joint effects of marine oil and simvastatin in patients with combined hyperlipidemia. Am J Cardiol. Sep. 15. 1997;80(6):797-8. [pmid: 9315596].
18 De Caterina R, Cipollone F, Filardo FP, et al. Low-density lipoprotein level reduction by the 3-hydroxy-3-methylglutaryl coenzyme-A inhibitor simvastatin is accompanied by a related reduction of F2-isoprostane formation in hypercholesterolemic subjects: no further effect of vitamin E. Circ Cardiovasc Qual Outcomes. Nov. 12. 2002;106(20):2543-9. [pmid: 12427649].
19 Dehmer GJ, Popma JJ, van den Berg EK, et al. Reduction in the rate of early restenosis after coronary angioplasty by a diet supplemented with n-3 fatty acids. N Engl J Med. Sep. 22. 1988;319(12):733-40. [pmid: 2842680].
20 Desideri G, Croce G, Tucci M, et al. Effects of bezafibrate and simvastatin on endothelial activation and lipid peroxidation in hypercholesterolemia: evidence of different vascular protection by different lipid-lowering treatments. J Clin Endocrinol Metab. Nov. 2003;88(11):5341-7. [pmid: 14602771].
21 Di Spirito M, Morelli G, Doyle RT, et al. Effect of omega-3-acid ethyl esters on steady-state plasma pharmacokinetics of atorvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2939-45. [pmid: 19006470].
22 Dmoszynska-Giannopoulou A, Janicka L, Sokolowska B, et al. The effect of sulphinpyrazone and alpha-tocopherol on platelet activation and function in haemodialysed patients. Int Urol Nephrol. 1990;22(6):561-6. [pmid: 2093696].
23 Duffy SJ, O'Brien RC, New G, et al. Effect of anti-oxidant treatment and cholesterol lowering on resting arterial tone, metabolic vasodilation and endothelial function in the human forearm: a randomized, placebo-controlled study. Clin Exp Pharmacol Physiol. May. 2001;28(5–6):409-18. [pmid: 11380515].
24 Eritsland J, Arnesen H, Gronseth K, et al. Effect of dietary supplementation with n-3 fatty acids on coronary artery bypass graft patency. Am J Cardiol. Jan. 1. 1996;77(1):31-6. [pmid: 8540453].
25 Ferraro PM, Ferraccioli GF, Gambaro G, et al. Combined treatment with renin-angiotensin system blockers and polyunsaturated fatty acids in proteinuric IgA nephropathy: a randomized controlled trial. Nephrol Dial Transplant. Jan. 2009;24(1):156-60. [pmid: 18685141].
26 Gardner CD, Zehnder JL, Rigby AJ, et al. Effect of Ginkgo biloba (EGb 761) and aspirin on platelet aggregation and platelet function analysis among older adults at risk of cardiovascular disease: a randomized clinical trial. Blood Coagul Fibrinolysis. Dec. 2007;18(8):787-93. [pmid: 17982321].
27 Garg RK, Nag D, Agrawal A. A double blind placebo controlled trial of ginkgo biloba extract in acute cerebral ischaemia. J Assoc Physicians India. Nov. 1995;43(11):760-3. [pmid: 8773035].
28 Ghatak A, Brar MJ, Agarwal A, et al. Oxy free radical system in heart failure and therapeutic role of oral vitamin E. Int J Cardiol. Dec. 6. 1996;57(2):119-27. [pmid: 9013263].
29 Glynn RJ, Ridker PM, Goldhaber SZ, et al. Effects of random allocation to vitamin E supplementation on the occurrence of venous thromboembolism: report from the Women's Health Study. Circ Cardiovasc Qual Outcomes. Sep. 25. 2007;116(13):1497-503. [pmid: 17846285].
30 Gosai P, Liu J, Doyle RT, et al. Effect of omega-3-acid ethyl esters on the steady-state plasma pharmacokinetics of rosuvastatin in healthy adults. Expert Opin Pharmacother. Dec. 2008;9(17):2947-53. [pmid: 19006471].
31 Govil MK, Agrawal BD, Gupta BK, et al. The role of magnesium in digitalis--induced arrhythmias. J Assoc Physicians India. Dec. 1979;27(12):1059-65. [pmid: 549914].
32 Hansen JB, Lyngmo V, Svensson B, et al. Inhibition of exercise-induced shortening of bleeding time by fish oil in familial hypercholesterolemia (type IIa). Arterioscler Thromb. Jan. 1993;13(1):98-104. [pmid: 8422345].
33 Howe PR, Lungershausen YK, Cobiac L, et al. Effect of sodium restriction and fish oil supplementation on BP and thrombotic risk factors in patients treated with ACE inhibitors. J Hum Hypertens. Jan. 1994;8(1):43-9. [pmid: 8151606].
34 Isley WL, Miles JM, Harris WS. Pilot study of combined therapy with omega-3 fatty acids and niacin in atherogenic dyslipidemia. J Clin Lipidol. 2007;1(3):211-7. [pmid: 21291683].
35 Jiang X, Williams KM, Liauw WS, et al. Effect of ginkgo and ginger on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects. Br J Clin Pharmacol. Apr. 2005;59(4):425-32. [pmid: 15801937].
36 Jiang X, Williams KM, Liauw WS, et al. Effect of St John's wort and ginseng on the pharmacokinetics and pharmacodynamics of warfarin in healthy subjects.[Erratum appears in Br J Clin Pharmacol. 2004 Jul;58(1):102]. Br J Clin Pharmacol. May. 2004;57(5):592-9. [pmid: 15089812].
37 Kaul U, Sanghvi S, Bahl VK, et al. Fish oil supplements for prevention of restenosis after coronary angioplasty. Int J Cardiol. Apr. 1992;35(1):87-93. [pmid: 1563884].
38 Kim BH, Kim KP, Lim KS, et al. Influence of Ginkgo biloba extract on the pharmacodynamic effects and pharmacokinetic properties of ticlopidine: an open-label, randomized, two-period, two-treatment, two-sequence, single-dose crossover study in healthy Korean male volunteers. Clin Ther. Feb. 2010;32(2):380-90. [pmid: 20206795].
39 Lankin VZ, Tikhaze AK, Kukharchuk VV, et al. Antioxidants decreases the intensification of low density lipoprotein in vivo peroxidation during therapy with statins. Mol Cell Biochem. Jul. 2003;249(1–2):129-40. [pmid: 12956408].
40 Lazzarin N, Vaquero E, Exacoustos C, et al. Low-dose aspirin and omega-3 fatty acids improve uterine artery blood flow velocity in women with recurrent miscarriage due to impaired uterine perfusion. Fertil Steril. Jul. 2009;92(1):296-300. [pmid: 18692841].
41 Lee SH, Ahn YM, Ahn SY, et al. Interaction between warfarin and Panax ginseng in ischemic stroke patients. J Altern Complement Med. Jul. 2008;14(6):715-21. [pmid: 18637764].
42 Liu M, Wallmon A, Wallin R, et al. Effects of stable fish oil and simvastatin on plasma lipoproteins in patients with hyperlipidemia. Nutr Res. 2003;23(8):1027-34.
43 Lu WJ, Huang JD, Lai ML. The effects of ergoloid mesylates and ginkgo biloba on the pharmacokinetics of ticlopidine. J Clin Pharmacol. Jun. 2006;46(6):628-34. [pmid: 16707409].
44 Lungershausen YK, Howe PR. Improved detection of a blood pressure response to dietary intervention with 24-hour ambulatory monitoring. Am J Hypertens. Dec. 1994;7(12):1115-7. [pmid: 7702808].
45 Mabuchi H, Nohara A, Kobayashi J, et al. Effects of CoQ10 supplementation on plasma lipoprotein lipid, CoQ10 and liver and muscle enzyme levels in hypercholesterolemic patients treated with atorvastatin: a randomized double-blind study. Atherosclerosis. Dec. 2007;195(2):e182-e189. [pmid: 17681347].
46 Macan H, Uykimpang R, Alconcel M, et al. Aged garlic extract may be safe for patients on warfarin therapy. J Nutr. Mar. 2006;136(3 Suppl):793S-5S. [pmid: 16484565].
47 Maki KC, McKenney JM, Reeves MS, et al. Effects of adding prescription omega-3 acid ethyl esters to simvastatin (20 mg/day) on lipids and lipoprotein particles in men and women with mixed dyslipidemia.[Erratum appears in Am J Cardiol. 2008 Nov 15;102(10):1425]. Am J Cardiol. Aug. 15. 2008;102(4):429-33. [pmid: 18678300].
48 Manuel YK, Vinckx M, Vertommen J, et al. Impact of Vitamin E supplementation on lipoprotein peroxidation and composition in Type 1 diabetic patients treated with Atorvastatin. Atherosclerosis. Aug. 2004;175(2):369-76. [pmid: 15262194].
49 Mauro VF, Mauro LS, Kleshinski JF, et al. Impact of ginkgo biloba on the pharmacokinetics of digoxin. Am J Ther. Jul. 2003;10(4):247-51. [pmid: 12845387].
50 McDowell IF, Brennan GM, McEneny J, et al. The effect of probucol and vitamin E treatment on the oxidation of low-density lipoprotein and forearm vascular responses in humans. Eur J Clin Invest. Nov. 1994;24(11):759-65. [pmid: 7890014].
51 McKenney JM, Swearingen D, Di SM, et al. Study of the pharmacokinetic interaction between simvastatin and prescription omega-3-acid ethyl esters. J Clin Pharmacol. Jul. 2006;46(7):785-91. [pmid: 16809804].
52 Meyer BJ, Hammervold T, Rustan AC, et al. Dose-dependent effects of docosahexaenoic acid supplementation on blood lipids in statin-treated hyperlipidaemic subjects. Lipids. Mar. 2007;42(2):109-15. [pmid: 17393216].
53 Micheletta F, Natoli S, Misuraca M, et al. Vitamin E supplementation in patients with carotid atherosclerosis: reversal of altered oxidative stress status in plasma but not in plaque. Arterioscler Thromb Vasc Biol. Jan. 2004;24(1):136-40. [pmid: 14592846].
54 Miyamoto S, Kawano H, Takazoe K, et al. Vitamin E improves fibrinolytic activity in patients with coronary spastic angina. Thromb Res. 2004;113(6):345-51. [pmid: 15226088].
55 Mohammed Abdul MI, Jiang X, Williams KM, et al. Pharmacodynamic interaction of warfarin with cranberry but not with garlic in healthy subjects. Br J Pharmacol. Aug. 2008;154(8):1691-700. [pmid: 18516070].
56 Motoyama T, Kawano H, Kugiyama K, et al. Vitamin E administration improves impairment of endothelium-dependent vasodilation in patients with coronary spastic angina. J Am Coll Cardiol. Nov. 15. 1998;32(6):1672-9. [pmid: 9822095].
57 Mueller BA, Talbert RL, Tegeler CH, et al. The bleeding time effects of a single dose of aspirin in subjects receiving omega-3 fatty acid dietary supplementation. J Clin Pharmacol. Feb. 1991;31(2):185-90. [pmid: 2010565].
58 Napoli C, Leccese M, Palumbo G, et al. Effects of vitamin E and HMG-CoA reductase inhibition on cholesteryl ester transfer protein and lecithin-cholesterol acyltransferase in hypercholesterolemia. Coron Artery Dis. 1998;9(5):257-64. [pmid: 9710685].
59 Nordøy A, Bonaa KH, Sandset PM, et al. Effect of omega-3 fatty acids and simvastatin on hemostatic risk factors and postprandial hyperlipemia in patients with combined hyperlipemia. Arterioscler Thromb Vasc Biol. Jan. 2000;20(1):259-65. [pmid: 10634827].
60 Nordøy A, Svensson B, Hansen JB. Atorvastatin and omega-3 fatty acids protect against activation of the coagulation system in patients with combined hyperlipemia. J Thromb Haemost. 2003;1(4):690-7. [pmid: 12871402].
61 Paolisso G, Gambardella A, Giugliano D, et al. Chronic intake of pharmacological doses of vitamin E might be useful in the therapy of elderly patients with coronary heart disease. Am J Clin Nutr. Apr. 1995;61(4):848-52. [pmid: 7702030].
62 Paolisso G, Di Maro G, Cozzolino D, et al. Chronic magnesium administration enhances oxidative glucose metabolism in thiazide treated hypertensive patients. Am J Hypertens. Oct. 1992;5(10):681-6. [pmid: 1418829].
63 Playford DA, Watts GF, Croft KD, et al. Combined effect of coenzyme Q10 and fenofibrate on forearm microcirculatory function in type 2 diabetes. Atherosclerosis. May. 2003;168(1):169-79. [pmid: 12732401].
64 Radaelli A, Cazzaniga M, Viola A, et al. Enhanced Baroreceptor Control of the Cardiovascular System by Polyunsaturated Fatty Acids in Heart Failure Patients. J Am Coll Cardiol. 2006;48(8):1600-6. [pmid: 17045894].
65 Reyes AJ, Leary WP, Acosta-Barrios TN, et al. Magnesium supplementation in hypertension treated with hydrochlorothiazide. Curr Ther Res, Clin Exp. 1984;36(2):332-40.
66 Rombouts EK, Rosendaal FR, van der Meer FJ. Daily vitamin K supplementation improves anticoagulant stability. J Thromb Haemost. Oct. 2007;5(10):2043-8. [pmid: 17666020].
67 Roth EM, Bays HE, Forker AD, et al. Prescription omega-3 fatty acid as an adjunct to fenofibrate therapy in hypertriglyceridemic subjects. J Cardiovasc Pharmacol. Sep. 2009;54(3):196-203. [pmid: 19597368].
68 Sconce E, Avery P, Wynne H, et al. Vitamin K supplementation can improve stability of anticoagulation for patients with unexplained variability in response to warfarin. Blood. Mar. 15. 2007;109(6):2419-23. [pmid: 17110451].
69 Steiner M, Glantz M, Lekos A. Vitamin E plus aspirin compared with aspirin alone in patients with transient ischemic attacks. Am J Clin Nutr. Dec. 1995;62(6 Suppl):1381S-4S. [pmid: 7495235].
70 Sutken E, Inal M, Ozdemir F. Effects of vitamin E and gemfibrozil on lipid profiles, lipid peroxidation and antioxidant status in the elderly and young hyperlipidemic subjects. Saudi Med J. Apr. 2006;27(4):453-9. [pmid: 16598319].
71 Svaneborg N, Kristensen SD, Hansen LM, et al. The acute and short-time effect of supplementation with the combination of n-3 fatty acids and acetylsalicylic acid on platelet function and plasma lipids. Thromb Res. Feb. 15. 2002;105(4):311-6. [pmid: 12031825].
72 Tankanow R, Tamer HR, Streetman DS, et al. Interaction study between digoxin and a preparation of hawthorn (Crataegus oxyacantha). J Clin Pharmacol. Jun. 2003;43(6):637-42. [pmid: 12817526].
73 Tousoulis D, Antoniades C, Vassiliadou C, et al. Effects of combined administration of low dose atorvastatin and vitamin E on inflammatory markers and endothelial function in patients with heart failure. Eur J Heart Fail. 2005;7(7):1126-32. [pmid: 16051518].
74 Watson PS, Scalia GM, Galbraith A, et al. Lack of effect of coenzyme Q on left ventricular function in patients with congestive heart failure. J Am Coll Cardiol. 1999;33(6):1549-52. [pmid: 10334422].
75 Wirell MP, Wester PO, Stegmayr BG. Nutritional dose of magnesium in hypertensive patients on beta blockers lowers systolic blood pressure: a double-blind, cross-over study. J Intern Med. Aug. 1994;236(2):189-95. [pmid: 7913949].
76 Wolf HR. Does Ginkgo biloba special extract EGb 761 provide additional effects on coagulation and bleeding when added to acetylsalicylic acid 500 mg daily?. Drugs in R & D. 2006;7(3):163-72. [pmid: 16752942].
77 Yamamoto H, Yoshimura H, Noma M, et al. Improvement of coronary vasomotion with eicosapentaenoic acid does not inhibit acetylcholine-induced coronary vasospasm in patients with variant angina.[Erratum appears in Jpn Circ J 1995 Nov;59(11):773–4]. Jpn Circ J. Sep. 1995;59(9):608-16. [pmid: 7500544].
78 Young JM, Florkowski CM, Molyneux SL, et al. Effect of coenzyme Q(10) supplementation on simvastatin-induced myalgia. Am J Cardiol. Nov. 1. 2007;100(9):1400-3. [pmid: 17950797].
79 Yuan CS, Wei G, Dey L, et al. Brief communication: American ginseng reduces warfarin's effect in healthy patients: a randomized, controlled Trial. Ann Intern Med. Jul. 6. 2004;141(1):23-7. [pmid: 15238367].
80 Whitlock RP, Crowther MA, Warkentin TE, et al. Warfarin cessation before cardiopulmonary bypass: lessons learned from a randomized controlled trial of oral vitamin K. Ann Thorac Surg. Jul. 2007;84(1):103-8. [pmid: 17588394].
81 Pernice W, Beckmann R, Ketelsen UP, et al. A double-blind placebo controlled trial of diltiazem in Duchenne dystrophy. Klin Wochenschr. Jul. 1. 1988;66(13):565-70. [pmid: 2463406].