# Scientific Information Packet Requests

Appendix B lists the names of the companies contacted from which to obtain scientific information packets.

Name of Company
Abbott Laboratories | Lundbeck, Inc.
Actelion Pharmaceuticals US, Inc | Meda Pharmaceuticals
Alcon Laboratories, Inc. | Merck & Co., Inc.
Apothecon B.V. | Mutual Pharma (URL Pharma Inc)
AstraZeneca Pharmaceuticals, LP | Mylan Pharmaceuticals
AstraZeneca Pharmaceuticals, LP | Mylan Pharmaceuticals
Aton Pharma Inc. | NitroMed, Inc.
Bayer HealthCare Pharmaceuticals | NovaDel Pharma
Biovail Pharmaceuticals Inc. | Novartis Pharmaceuticals Corporation
Boehringer Ingelheim Pharmaceuticals, Inc. | Otsuka America Pharmaceutical, Inc.
Bristol-Myers Squibb | Paddock Laboratories, Inc.
Daiichi Sankyo, Inc | Pfizer Inc
Duramed Subsidiary of Barr Pharmaceuticals a.k.a. Teva | Prometheus Laboratories Inc.
Eisal Medical Research Inc. | Promius Pharma, LLC
EKR Therapeutics, Inc | Salix Pharmaceuticals
Eli Lilly & Co | Sandoz Inc
Ferndale | Sanofi Aventis US
Forest Pharmaceuticals | Santen Inc.
Forest Pharmaceuticals | Schering-Plough Corporation
G. Pohl-Boskamp GmbH & Co. KG | Shionogi Inc.
Gilead Sciences | Teva Pharmaceuticals USA
GlaxoSmithKline | Teva Pharmaceuticals USA
Graceway Pharmaceuticals, LLC | UCB, Inc
Hospira | United Therapeutics Corporation
Ivax Pharmaceuticals (Teva Pharmaceuticals) | Upsher-Smith Labratories, Inc
Johnson & Johnson Health Care Products & Pharmaceuticals | USL Pharmaceuticals
Key Pharmaceuticals | Validus Pharmaceuticals LLC
King Pharmaceuticals, Inc. | VIVUS, Inc.
LEO Pharma Inc. | Wyeth Pharmaceuticals Headquarters