# Search Strategies

Appendix A lists the exact search strings used for each database included in the search of the literature for this review.

## MEDLINE (1950 to September 1, 2011)

1. exp Dietary Supplements/
2. (Neutraceutical* or Nutraceutical* or (diet* adj1 supplement*) or (nutrition* adj1 supplement*) or (food$1 adj1 supplement*) or (botanic* adj1 supplement*)).ti,ab.
3. exp Vitamins/ or vitamin$1.ti,ab.
4. exp Minerals/ or exp Calcium/ or exp Chromium/ or exp Copper/ or exp Iron/ or exp Magnesium/ or exp Potassium/ or exp Selenium/ or (mineral$1 or bone meal or dicalcium or dolomite or chromium or copper or iron or magnesium or potassium or selenium).ti,ab.
5. (diet or diets or dietary or supplement*).ti,ab. or (dt or tu).fs.
6. (3 or 4) and 5
7. 1 or 2 or 6
8. exp Phytotherapy/
9. exp Plant Preparations/ or exp Plant Extracts/
10. exp Drugs, Chinese Herbal/ or exp Plants, Medicinal/
11. ((medicin* adj3 herb$2) or (medicin* adj3 plant$1) or (botanical* adj3 medicin*) or (botanical* adj3 drug$1) or (herb$2 adj3 drug$1) or (therapeutic* adj3 herb$2) or (therapeutic* adj3 plant$1) or (therapeutic* adj3 botanical*) or (plant$1 adj3 pharmacotherap*) or (plant$1 adj3 pharmaco-therap*) or (herb$2 adj3 pharmacotherap*) or (herb$2 adj3 pharmaco-therap*) or (botanical adj3 pharmacotherap*) or (botanical adj3 pharmaco-therap*) or (Chinese adj2 medicin*) or (Chinese adj2 medicin*) or (Chinese adj2 drug$1) or (Chinese adj2 pharmacotherap*) or (Chinese adj2 pharmaco-therap*) or phytochemical* or phyto-chemical* or phytonutrient* or phyto-nutrient* or phytotherap* or phyto-therap* or phytomedicin* or phyto-medicin*).ti,ab.
12. exp Folic Acid/
13. (folic acid$1 or folacin or folate or folvite or pteroylglutamic acid or "Vitamin M").ti,ab.
14. exp Glucosamine/ or glucosamin*.ti,ab.
15. exp Salvia miltiorrhiza/
16. (salvia miltiorrhiza or danshen or horse-racing grass$2 or rat-tail grass$2 or red-rooted sage$1 or red root$1 or red sage$1 or red sage root or (root$1 adj3 purple sage$1) or scarlet sage$1).ti,ab.
17. (Ch'ih shen or Chinese Salvia or dangshem or dan shen or dan-shen or danshensu or fufangdenshen or huang ken or hung ken or pin-ma ts'ao or Radix salviae miltiorrhizae or Salvia bowelyana or Salvia miltiorrhiza or Salvia przewalskii or Salvia root$1 or Salvia yunnanensis or sh'ih shen or shu-wei ts'ao or tan seng or tan-shen or tzu tan-ken or yunzhi-danshen).ti,ab.
18. exp Forskolin/ or (Forskolin or Coleus forskohlii or Indian Coleus or Coleonol).ti,ab.
19. exp Ruscus/ or (butcher$2 adj broom$1).ti,ab.
20. exp Cinnamomum zeylanicum/ or (Cinnamomum or Cinnamon*).ti,ab.
21. exp Taraxacum/ or (Taraxacum or dandelion* or blowball$1 or Irish daisy or Irish daisies or (pee adj3 bed) or (lion* adj2 tooth) or (lion* adj2 teeth) or (priest* adj2 crown$1)).ti,ab.
22. ((Dent adj2 lion$1) or huang hua di ding or yellow flower earth nail$1 or puffball$1 or swine snout$1).ti,ab.
23. exp Lycium/ or (wolfberr* or wolf berr* or gojiberr* or goji berr*).ti,ab.
24. exp Echinacea/ or (Echinacea or American coneflower$1 or purple coneflower$1 or Rudbeckia purpurea or Black Sampson or combflower$1 or Kansas snake root$1 or scurvy root$1).ti,ab.
25. exp Mentha piperita/ or exp Glycyrrhiza/ or (mentha piperita or peppermint$1 or glycyrrhiza or licorice$1 or liquorice$1).ti,ab.
26. exp Tanacetum parthenium/ or exp Tinospora/ or (Tanacetum parthenium or feverfew or (bachelor'* adj button$1) or featherfew or febrifuge plant$1 or featherfoil or tinospora or guduchi).ti,ab.
27. Chrysanthemum parthenium.ti,ab.
28. exp Garlic/
29. (garlic or allium or (nectar adj2 god$1) or pa-se-waa or poor man's treacle or stinking rose$1).ti,ab.
30. exp Ginkgo biloba/
31. (Ginkgo or Ginkgophyta or Maidenhair Tree$1 or Maiden Hair Tree$1 or Fossil Tree$1 or Duckfoot tree$1 or Duck foot tree$1 or Japanese silver apricot$1 or kew tree$1 or silver apricot$1).ti,ab.
32. exp Panax/
33. (Panax or Ginseng or Jen Shen or Ninjin or Renshen or Schinseng or Shinseng).ti,ab.
34. (Guggulipid$1 or guggul$1 or gugulipid$1 or gugulu or gugululipid$1 or guggulsterone$1 or yogaraj-guggulu).ti,ab.
35. (mukul or myrrh).ti,ab.
36. exp Gymnema/
37. (Gymnema or (Periploca adj3 wood$1) or small Indian ipecac or vishani or Sarpadarushtrika or Wakandi).ti,ab.
38. exp Crataegus/ or (hawthorn$2 or Crataegus oxycantha or (bread adj2 cheese tree$1) or cockspur thorn$1 or Chinese hawthorn$2 or May bush$2 or May tree$1 or May blossom$1 or May flower$1 or mayflower$1 or quickset or thorn-apple tree$1 or thornapple tree$1 or white thorn$1 or whitethorn$1).ti,ab.
39. exp Convallaria/
40. (Convallaria or (lily adj3 valley) or lady$2 tears or ladies tears or may lily or may lilies or may bell$1 or maybell$1 or conval lily or conval lilies or lily constancy or (ladder$1 adj2 heaven) or male lily or male lilies).ti,ab.
41. exp Leonurus/
42. (Motherwort* or Leonorus cardiaca or lion$2 tail$1 or lion$2 ear$1 or throwwort*).ti,ab.
43. exp Milk Thistle/
44. (Milk Thistle$1 or Silybum marianum or Carduus marianus or Holy thistle$1 or marythistle$1 or Mary$2 thistle$1 or Marian$2 thistle$1).ti,ab.
45. exp Rauwolfia/
46. (Rauwolfia or Rauvolfia or Indian snakeroot$1 or Sarpa-gandha or Nakuli or Chota-chand or Kanakachandrika).ti,ab.
47. (red yeast rice extract* or Monascus purpureus or (mould species adj3 rice$1) or (red adj2 yeast$1) or (red adj2 rice$1) or red koji or red leaven$1).ti,ab.
48. exp Eleutherococcus/
49. (Eleutherococcus or Siberian ginseng or Ci wu ju or Eleuthero or "touch-me-not" or "touch-me-nots" or devil$2 shrub$1).ti,ab.
50. ((Thorny bearer adj2 free) or ussurian thorny pepperbrush$2 or ussurian thorny pepper brush$2).ti,ab.
51. exp Hypericum/
52. (Hypericum or John$2 wort$1 or Johnswort$1 or Amber or (touch adj2 heal) or goat weed$1 or Hardhay$1 or Klamath weed$1 or Rosin rose$1 or Tipton weed$1 or (balm adj2 warrior$1)).ti,ab.
53. (Devil$2 scorge$1 or goatweed$1 or klammath weed$1).ti,ab.
54. exp Curcuma/
55. (Turmeric or curcuma or Indian saffron or Indian yellow root$1 or Zedoary zedoaria).ti,ab.
56. exp Valerian/
57. (Valerian* or vandal root$1 or all-heal$1 or setwall$1).ti,ab.
58. exp Selenoproteins/ or Selenoprotein$1.ti,ab.
59. exp Thioctic Acid/ or (thioctic acid$1 or Alpha lipoic acid$1 or Alpha-Lipogamma or Alpha-Lipon Stada or alpha-Liponaure Heumann or Alpha-Liponsaure or Alpha-Lippon or alpha-Vibolex or Alphaflam).ti,ab.
60. ("Coenzyme Q10" or "CoQ 10" or CoQ10 or idebenone or ubiquinone or ubidecarenone or ubisemiquinone or "vitamin q10").ti,ab.
61. exp Fish Oils/
62. (fish adj2 oil$1).ti,ab.
63. exp Fatty Acids, Omega-3/
64. ("omega 3" or "omega 3s" or omega three$1 or "n-3 Fatty Acid" or "n-3 Fatty Acids" or "n3 Fatty Acid" or "n3 Fatty Acids" or "n-3 Polyunsaturated Fatty Acid" or "n-3 Polyunsaturated Fatty Acids" or "n3 Polyunsaturated Fatty Acid" or "n3 Polyunsaturated Fatty Acids" or "n-3 PUFA" or "n3 PUFA").ti,ab.
65. (Eicosapentanoic acid$1 or decosahexanoic acid$1 or alpha linoleic acid$1).ti,ab.
66. (green tea$1 or black tea$1 or Camellia sinensis or Japanese tea$1 or Matsu-cha tea$1).ti,ab.
67. exp Phytosterols/
68. (Phytosterol$1 or plant sterol$1 or plant stanol$1 or Beta-sitosterol$1 or sterolin$1).ti,ab.
69. exp beta-Glucans/
70. beta-Glucan$1.ti,ab.
71. exp Kava/
72. (kava or kawa or Piper methysticum).ti,ab.
73. exp Psyllium/
74. (Psyllium or Plantago ovata or flea seed$1 or fleawort or hemicelluloses or plantago seed$1 or ispaghula husk$1 or ispagula husk$1 or ispaghula seed$1 or ispagula seed$1 or Plantago arenaria or Plantago isphagula or Plantago ispagula).ti,ab.
75. exp Soy Foods/
76. (soy or miso or natto or tempeh or tofu).ti,ab.
77. exp Arginine/
78. (Arginine or L-Arginine).ti,ab.
79. (Chia or Salvia columbariae or Salvia hispanica or salba).ti,ab.
80. exp Chitosan/
81. (Chitin or chitosan or "N-carboxybutyl" or Poliglusam).ti,ab.
82. exp Cynara/
83. (Cynara or globe artichoke$1 or cardoon$1).ti,ab.
84. exp Carnitine/
85. (Carnitine or Bicarnesine or "L-Carnitine" or Levocarnitine or "Vitamin BT" or "Acetyl-L-carnitine" or carnitene or carnitor or canitor or "D-carnitine" or "D,L-carnitine" or "L-acetyl-carnitine" or "L-carnitina" or "L-carnitine" or "L-tartrate" or "L-CARNIPURE" or levacecarnine or levocarnitine or "L-propionylcarnitine" or "propionil-L-carnitine" or "propionyl-L-carnitine" or ST261).ti,ab.
86. (Pantethine or "Vitamin B5" or bile acid sequestrant$1 or cyproheptadine or cysteamine or "D-pantethine" or pantetheine or pantetheinase or Pantetina or panthenol or pantomin or pantosin or pantothenic acid$1 or sulfopantetheine).ti,ab.
87. (Policosanol$1 or D003 or hexacontanol$1 or isopolicosanol$1 or "Octa-60" or octacosanoic acid$1 or octacosanol$1 or ricewax$2 or winteriser cake$1 or winterizer cake$1 or sugar cane policosanol$1 or sunflower seed policosanol$1 or triacontanol* or wheat germ policosanol$1).ti,ab.
88. exp Withania/ or (Withania or Ashwaganda or Indian ginseng or winter cherry or winter cherries or wintercherry or wintercherries or Ayurvedic ginseng).ti,ab.
89. exp Aesculus/ or exp Aloe/ or (aesculus or buckeye$1 or horse chestnut$1 or conqueror tree$1 or aloe vera or aloe barbadensis).ti,ab.
90. exp Ginger/ or (ginger or Zingiber officinale or Gamma oryzanol).ti,ab.
91. exp Ephedra/ or exp Trigonella/ or (ephedra or ginger trigonella or fenugreek or foenumgraecum or poenumgraecum).ti,ab.
92. (Gamma oryzanol or dong quai or tetrandrine or tetradrine or hanjisong).ti,ab.
93. exp Hydrastis/
94. (hydrastis or Golden Seal or Goldenseal).ti,ab.
95. or/7–94
96. exp Functional Food/
97. (functional food$1 or (therapeutic* adj2 food$1)).ti,ab.
98. Citrus paradisi/ or Vaccinium macrocarpon/ or Viburnum/ or Blueberry Plant/ or Punicaceae/
99. (Citrus paradisi or Vaccinium macrocarpon or Viburnum or Punicaceae or blueberr* or cranberr* or grapefruit* or Toronja* or pomegranate* or Punica granatum or bitter orange or citrus auranticum or kijitsu or shangzhou zhiqiao or zhi shi).ti,ab.
100. exp beverages/ or (beverage* or drink* or juice* or tea or teas).ti,ab.
101. (98 or 99) and 100
102. exp Plant oils/ or exp Olea/
103. ((botanic* or plant or plants or vegetable* or clove or cloves or corn or corns or cottonseed* or croton* or olive or olives or safflower* or sesame* or soybean* or teatree*) and (oil or oils)).ti,ab.
104. Linaceae/ or Flax/ or (Linaceae or flax or flaxseed* or Linum or linseed*).ti,ab.
105. exp Dietary Fiber/ or ((diet or diets or dietary) and (fibre or fibres or fiber or fibers or roughage or (wheat adj bran) or cereal*)).ti,ab.
106. exp Caffeine/ or caffein*.ti,ab.
107. or/102–106
108. 96 or 97 or 101 or 107
109. 95 or 108
110. exp Cardiovascular diseases/dt
111. exp Adrenergic beta-Antagonists/
112. (Adrenergic adj2 Antagonist*).ti,ab.
113. ((beta adj1 Adrenergic adj2 block*) or beta block*).ti,ab.
114. exp Acebutolol/
115. (acebutolol or acebutalol or Apo-Acebutolol or Apo-Acebulalol or Sectral or Prent).ti,ab.
116. exp Betaxolol/
117. (betaxolol or Kerlon or Kerlone).ti,ab.
118. exp Bisoprolol/
119. (bisoprolol or Concor or Concore or Zebeta or Monocor).ti,ab.
120. (carvedilol or Apo-carvedilol or Coreg or Dilatrend or Eucardic or Kredex).ti,ab.
121. exp Labetalol/
122. (labetalol or Labetolol or Normodyne or Trandate).ti,ab.
123. exp Metoprolol/
124. (metoprolol or Betaloc or Betalok or Lopressor or Seloken).ti,ab.
125. exp Nadolol/
126. (nadolol or Corgard or Solgol).ti,ab.
127. (nebivolol or Nebilet or Silostar).ti,ab.
128. exp Pindolol/
129. (pindolol or Visken).ti,ab.
130. exp Propranolol/
131. (propranolol or Avlocardyl or Deralin or Dociton or Inderal or Obsidan).ti,ab.
132. exp Sotalol/
133. (sotalol or Darob).ti,ab.
134. exp Timolol/
135. (timolol or Blocadren).ti,ab.
136. exp Calcium Channel Blockers/
137. ((calcium block* adj2 exogenous) or (calcium antagonist* adj2 exogenous) or (calcium inhibitor* adj2 exogenous) or calcium channel block*).ti,ab.
138. (Dihydropyridine or Lemildipine).ti,ab.
139. exp Amlodipine/
140. (amlodipine or Norvasc or Istin).ti,ab.
141. exp Felodipine/
142. (felodipine or Plendil or Renedil).ti,ab.
143. exp Isradipine/
144. (isradipine or DynaCirc or Lomir or Prescal).ti,ab.
145. exp Nicardipine/
146. (nicardipine or Cardene).ti,ab.
147. exp Nifedipine/
148. (nifedipine or Adalat or Cordipin or Nifediac or Nifedical or Procardia).ti,ab.
149. exp Nimodipine/
150. (nimodipine or Nimotop).ti,ab.
151. exp Nisoldipine/
152. (nisoldipine or Sular).ti,ab.
153. exp Diltiazem/
154. (diltiazem or Cardizem or Dilacor or Dilzem or Tiazac).ti,ab.
155. exp Verapamil/
156. (verapamil or Bosoptin or Calan or Cordilox or Covera-HS or Isoptin or Iproveratril or Verelan).ti,ab.
157. exp Angiotensin-Converting Enzyme Inhibitors/
158. ((Angiotensin-Converting Enzyme adj1 Inhibitor*) or ACE inhibitor* or (Angiotensin-Converting Enzyme adj1 antagonist*)).ti,ab.
159. (dipeptidyl carboxypeptidase inhibitor* or (Kininase II adj2 inhibitor*) or (Kininase II adj2 antagonist*)).ti,ab.
160. (benazepril or Cibacen or Lotensin).ti,ab.
161. exp Captopril/
162. (captopril or Capoten or Lopirin).ti,ab.
163. exp Enalapril/
164. (enalapril or Renitec or Renitek or Vasotec).ti,ab.
165. exp Fosinopril/
166. (fosinopril or Dynacil or Fozitec or Monopril or Staril or Tensocardil).ti,ab.
167. exp Lisinopril/
168. (lisinopril or Lysinopril or Prinivil or Zestril).ti,ab.
169. (moexipril or Perdix or Univasc).ti,ab.
170. exp Perindopril/
171. (perindopril or Aceon or Coversyl or Prestarium).ti,ab.
172. (Quinapril or Accupril).ti,ab.
173. exp Ramipril/
174. (Ramipril or Acovil or Altace or Triatec or Tritace or Vesdil).ti,ab.
175. (Trandolapril or Gopten or Mavik or Odrik).ti,ab.
176. (Candesartan or Atacand).ti,ab.
177. (eprosartan or Teveten).ti,ab.
178. (irbesartan or Aprovel or Avapro or Karvea).ti,ab.
179. exp Losartan/
180. (losartan or Cozaar).ti,ab.
181. (olmesartan or Benicar).ti,ab.
182. (telmisartan or Micardis or Pritor).ti,ab.
183. (valsartan or Diovan).ti,ab.
184. ((Renin adj1 Inhibit*) or Renin antagonist*).ti,ab.
185. (Aliskiren or Tekturna).ti,ab.
186. aldosterone receptor antagonist$1.ti,ab.
187. (Eplerenone or Inspra).ti,ab.
188. exp Spironolactone/
189. (Spironolactone or Aldactone or Verospirone).ti,ab.
190. exp Vasodilator Agents/
191. Vasodilator$1.ti,ab.
192. exp Clonidine/
193. (clonidine or Apo-Clonidine or Catapres or Duraclon).ti,ab.
194. exp Guanabenz/
195. (guanabenz or Wytensin).ti,ab.
196. exp Guanfacine/
197. (guanfacine or Intuniv or Tenex).ti,ab.
198. exp Methyldopa/
199. (Methyldopa or Apo-Methyldopa or Aldoril or Aldomet or Dopamet or Dopegyt).ti,ab.
200. exp Diazoxide/
201. (Diazoxide or Hyperstat or Proglycem).ti,ab.
202. exp Hydralazine/
203. (Hydralazine or Apo-Hydralazine or Apresoline or Dralzine).ti,ab.
204. exp Minoxidil/
205. (minoxidil or Loniten).ti,ab.
206. exp Isosorbide Dinitrate/
207. (Isosorbide Dinitrate or Dilatrate or Cedocard or Isoket or Isotrate or Isordil or Sorbitrate).ti,ab.
208. exp Nitroglycerin/
209. (nitroglycerin$1 or Natispray or Nitro-Dur or Nitromist or Nitrospan or Nitrostat or Nitro-Time or Transderm Nitro or Tridil or Trinipatch).ti,ab.
210. exp Phosphodiesterase inhibitors/
211. ((Phosphodiesterase adj1 Inhibit*) or (Phosphodiesterase adj1 antagonist*) or Antiphosphodiesterase$1 or Anti-phosphodiesterase$1 or (Phosphoric Diester Hydrolase adj1 Inhibit*) or (Phosphoric Diester Hydrolase adj1 antagonist*)).ti,ab.
212. (sildenafil or Revatio or tadalafil or vardenafil).ti,ab.
213. (Cilostazol or Pletal).ti,ab.
214. exp Alprostadil/
215. Alprostadil.ti,ab.
216. exp Epoprostenol/
217. (Epoprostenol or Flolan).ti,ab.
218. exp iloprost/
219. (iloprost or Ciloprost or Ventavis).ti,ab.
220. (Endothelin antagonist$1 or (Endothelin adj1 inhibit*)).ti,ab.
221. (treprostinil or Remodulin or bosentan or Tracleer or ambrisentan or Letairis).ti,ab.
222. exp Papaverine/
223. papaverine.ti,ab.
224. exp Isoxsuprine/
225. (isoxsuprine or Duvadilan).ti,ab.
226. exp Adrenergic alpha-Antagonists/
227. ((alpha-Adrenergic adj2 block*) or (Adrenergic alpha adj2 block*) or (alpha-Adrenergic adj2 antagonist*) or (Adrenergic alpha adj2 antagonist*) or (alpha block* adj2 adrenergic) or (alpha antagonist* adj2 adrenergic)).ti,ab.
228. exp Doxazosin/
229. (doxazosin or Cardura or Carduran or Diblocin or Doxazomerck or Doxazosin or Progandol).ti,ab.
230. exp Prazosin/
231. (prazosin or Minipress or Furazosin or Pratsiol).ti,ab.
232. (terazosin or Adecur or Apo-Terazosin or Deflox or Dysalfa or Flotrin or Heitrin or Hytrin or Hytrine or Magnurol).ti,ab.
233. exp Anti-Arrhythmia Agents/
234. ((Anti-Arrhythmia or Anti-Arrhythmic* or Antiarrhythmia or Antiarrhythmic* or Anti-fibrillatory or Antifibrillatory) and (drug or drugs or agent or agents or medication* or prescription*)).ti,ab.
235. exp Disopyramide/
236. (disopyramide or Norpace or Rhythmodan).ti,ab.
237. exp Procainamide/
238. (procainamide or Apo-Procainamide or Biocoryl or Novocainamide or Novocamid or Procamide or Pronestyl or Procan or Procanbid).ti,ab.
239. exp Quinidine/
240. (quinidine or Apo-Quinidine or Chinidin or Quinidex or Quinora).ti,ab.
241. exp Mexiletine/ or Mexiletine.ti,ab.
242. exp Encainide/
243. (encainide or Enkaid).ti,ab.
244. exp Flecainide/
245. (Flecainide or Tambocor).ti,ab.
246. exp Propafenone/
247. (propafenone or Apo-Propafenone or Arythmol or Baxarytmon or Fenoprain or Rythmol or Rytmonorm).ti,ab.
248. exp Amiodarone/
249. (amiodarone or Amiodarona or Cordarone or Cordarex or Pacerone or Trangorex).ti,ab.
250. (dofetilide or Tikosyn).ti,ab.
251. (dronedarone or Multaq).ti,ab.
252. exp Cardiotonic Agents/
253. ((Cardiotonic or Cardioprotective or Cardio-tonic or Cardio-protective) and (drug or drugs or agent or agents or medication$1 or prescription$1)).ti,ab.
254. (cardiotonics or cardio-tonics or cardiac stimulant* or myocardial stimulant* or inotropic agent*).ti,ab.
255. exp Digoxin/
256. (digoxin or Digacin or Digitek or Dilanacin or Lanacordin or Lanicor or Lanoxicaps or Lanoxin or Lenoxin).ti,ab.
257. exp Antilipemic Agents/
258. (Antilipemic$1 or anti-lipemic$1 or hypolipidemic$1 or hypo-lipidemic$1).ti,ab.
259. ((Antilipemic or anti-lipemic or antihyperlipemic or anti-hyperlipemic or antihyperlipidemic or anti-hyperlipidemic or hypolipidemic or hypo-lipidemic) and (drug or drugs or agent or agents or medication* or prescription*)).ti,ab.
260. (antihyperlipemics or anti-hyperlipemics or antihyperlipidemics or anti-hyperlipidemics).ti,ab.
261. exp Cholestyramine Resin/
262. (cholestyramin$1 or colestyramin$1 or Cuemid or Quantalan or Questran).ti,ab.
263. exp Colestipol/
264. (colestipol or Colestid).ti,ab.
265. (colesevelam or CholestaGel or Welchol).ti,ab.
266. (Bile acid sequestrant$1 or bile acid-binding drug$1 or bile acid-binding agent$1).ti,ab.
267. (Anticholesteremic$1 or Hypocholesteremic$1 or (cholesterol adj2 inhibitor$1) or cholesterol-lowering drug$1 or cholesterol-lowering agent$1 or cholesterol-lowering medication$1).ti,ab.
268. (ezetimibe or Zetia).ti,ab.
269. (fenofibrate or Antara or Fenoglide or Fibricor or Lipofen or Lofibra or TriCor or Triglide or Trilipix).ti,ab.
270. exp Gemfibrozil/
271. (Gemfibrozil or Apo-Gemfibrozil or Lopid or Trialmin).ti,ab.
272. ((Hydroxymethylglutaryl-CoA Reductase adj1 inhibit*) or (HMG-CoA Reductase adj1 inhibit*) or (Hydroxymethylglutaryl-CoA adj1 inhibit$) or (Hydroxymethylglutaryl-Coenzyme A adj1 inhibit$)).ti,ab.
273. (atorvastatin or Liptor).ti,ab.
274. (fluvastatin or Lescol).ti,ab.
275. exp Lovastatin/
276. (lovastatin or Altocor or Altoprev or Mevacor).ti,ab.
277. exp Pravastatin/
278. (pravastatin or Apo-Pravastatin or Lipostat or Pravasin$1 or Pravachol or Selektine).ti,ab.
279. (rosuvastatin or Crestor).ti,ab.
280. exp Simvastatin/
281. (simvastatin or Synvinolin or Zocor).ti,ab.
282. exp Niacin/
283. (niacin or Niacor or Niaspan or Nicobid or Nicolar or Nicotinex or Slo-Niacin).ti,ab.
284. exp Anticoagulants/
285. (Anticoagulant$1 or anti-coagulant$1 or bloodthinn* or blood-thinn*).ti,ab.
286. exp Warfarin/
287. (warfarin or Apo-Warfarin or Coumadin$1).ti,ab.
288. exp Dalteparin/
289. (dalteparin or Fragmin$1).ti,ab.
290. exp Heparin/
291. heparin.ti,ab.
292. (tinzaparin or Innohep).ti,ab.
293. exp Platelet Aggregation Inhibitors/
294. (antithrombocytic* or anti-thrombocytic* or (platelet$1 adj2 inhibit*) or Antiplatelet$1 or Anti-platelet$1 or Platelet Antagonist$1 or Platelet Antiaggregant$1).ti,ab.
295. exp Aspirin/
296. (Aspirin or Acetylsalicylic or Acylpyrin or Aloxiprimum or Aspergum or Bufferin or Colfarit or Dispril or Ecotrin or Easprin or Endosprin or Magnecyl or Micristin or Polopirin or Polopiryna or Solprin or Solupsan or Zorprin).ti,ab.
297. exp Ticlopidine/
298. (ticlopidine or Ticlid).ti,ab.
299. (clopidogrel or Plavix).ti,ab.
300. exp Diuretics/
301. (diuretic$1 or water pill$1).ti,ab.
302. exp Bumetanide/
303. (Bumetanide or bumex).ti,ab.
304. exp Ethacrynic Acid/
305. (etacrynic acid or ethacrynic acid or Edecrin).ti,ab.
306. exp Furosemide/
307. (furosemide or Errolon or Fursemide or Fusid or Lasix).ti,ab.
308. (torsemide or Demadex or torasemide).ti,ab.
309. (k-sparing or potassium-sparing).ti,ab.
310. exp Amiloride/
311. (Amiloride or Amidal or Amiduret or Kaluril or Midamor or Midoride or Modamide).ti,ab.
312. exp Triamterene/
313. (triamterene or Dyrenium).ti,ab.
314. thiazide diuretic$1.ti,ab.
315. exp Bendroflumethiazide/
316. (Bendroflumethiazide or Bendrofluazide).ti,ab.
317. exp Chlorothiazide/
318. (chlorothiazide or Chlotride or Diuril).ti,ab.
319. exp Hydrochlorothiazide/
320. (hydrochlorothiazide or Apo-Hydro or Dichlotride or Esidrex or HydroDIURIL or Microzide or Oretic).ti,ab.
321. exp Methyclothiazide/
322. (methyclothiazide or Aquatensen or Enduron).ti,ab.
323. exp Polythiazide/
324. (polythiazide or Renese).ti,ab.
325. exp Chlorthalidone/
326. (chlorthalidone or Apo-Chlorthalidone or Hygroton or Thalitone).ti,ab.
327. exp Indapamide/
328. (indapamide or Lozol or Metindamide).ti,ab.
329. exp Metolazone/
330. (metolazone or Mykrox or Zaroxolyn or Zytanix).ti,ab.
331. or/110–330
332. exp Herb-Drug Interactions/
333. exp Food-Drug Interactions/
334. exp Drug Synergism/
335. ad.fs.
336. ct.fs.
337. de.fs.
338. me.fs.
339. pk.fs.
340. to.fs.
341. ci.fs.
342. (interact* or react* or contraindicat* or contra-indicat* or chemically induce* or enhanc* or potentiat* or synergis* or toxic or toxicit*).ti,ab.
343. or/332–342
344. 109 and 331 and 343
345. limit 344 to human
346. limit 344 to ("in data review" or "in process" or "pubmednotmedline")
347. 345 or 346
348. limit 347 to "reviews (specificity)"
349. meta analysis.pt.
350. exp meta-analysis as topic/
351. (meta-analy* or metanaly* or metaanaly* or met analy* or integrative research or integrative review* or integrative overview* or research integration or research overview* or collaborative review*).ti,ab.
352. (systematic review* or systematic overview* or technology assessment* or HTA or HTAs).ti,ab.
353. exp Technology assessment, biomedical/
354. health technology assessment winchester england.jn.
355. (evidence report technology assessment or evidence report technology assessment summary).jn.
356. or/349–355
357. 347 and 356
358. 348 or 357
359. (controlled clinical trial or randomized controlled trial).pt.
360. exp randomized controlled trials as topic/ or exp controlled clinical trials as topic/ or exp random allocation/ or exp double-blind method/ or exp single-blind method/ or exp placebos/
361. "controlled clinical trial".ti,ab.
362. (random* or RCT$1 or placebo*).ti,ab.
363. ((singl* or doubl* or trebl* or tripl*) and (mask* or blind* or dumm*)).ti,ab.
364. or/359–363
365. 347 and 364
366. 365 not 358
367. clinical trial.pt.
368. exp Clinical Trials as Topic/
369. "clinical trial".ti,ab.
370. evaluation studies.pt.
371. exp Evaluation Studies as Topic/
372. (volunteer or volunteers or open label* or nonrandom* or non random* or quasirandom* or quasi-random*).ti,ab.
373. exp Cohort Studies/ or exp Longitudinal Studies/ or exp Prospective Studies/ or exp Follow-Up Studies/ or exp Retrospective Studies/ or exp Case-Control Studies/
374. (cohort or cohorts or longitudinal or prospective or retrospective).ti,ab.
375. ((observational or follow-up or followup) adj stud*).ti,ab.
376. (population-based stud* or population-based analys* or population stud* or population analys*).ti,ab.
377. ((descriptive adj stud*) or (multidimensional adj stud*) or (multi-dimensional adj stud*) or (multicenter adj stud*) or (multi-center adj stud*) or (multicentr* adj stud*) or (multi-centr* adj stud*)).ti,ab.
378. exp Multicenter Study/ or exp Multicenter Studies as Topic/
379. Comparative Study.pt.
380. ((comparative adj study) or (comparative adj studies) or (case adj control*) or "case series" or (case adj comparison*) or (case adj history) or (case adj histories)).ti,ab.
381. or/367–380
382. 347 and 381
383. 382 not (358 or 365)
384. (ae or co or mo).fs.
385. exp Harm Reduction/ or exp Intraoperative Complications/ or exp Morbidity/ or exp Mortality/ or exp Postoperative Complications/ or exp Risk/ or exp Safety/ or exp Treatment Outcome/ or exp Teratogens/ or exp Abnormalities, Drug-Induced/
386. (adverse or complication* or harm or harms or harmful or harming or injurious or morbidit* or mortalit* or risk$1 or side effect$1 or undersirable or tolerability or teratogen* or safety).ti,ab.
387. or/384–386
388. 347 and 387
389. 388 not (358 or 365 or 382)

## AMED (1985 to September 1, 2011)

1. exp Dietary supplements/
2. (Neutraceutical* or Nutraceutical* or (diet* adj1 supplement*) or (nutrition* adj1 supplement*) or (food$1 adj1 supplement*) or (botanic* adj1 supplement*)).ti,ab.
3. exp Vitamins/ or vitamin$1.ti,ab.
4. exp Minerals/ or exp Calcium/ or exp Chromium/ or exp Copper/ or exp Iron/ or exp Magnesium/ or exp Potassium/ or exp Selenium/ or (mineral$1 or bone meal or dicalcium or dolomite or chromium or copper or iron or magnesium or potassium or selenium).ti,ab.
5. (diet or diets or dietary or supplement*).ti,ab.
6. (3 or 4) and 5
7. 1 or 2 or 6
8. exp Phytotherapy/
9. exp plant extracts/ or exp plants medicinal/ or exp Herbal Drugs/
10. ((medicin* adj3 herb$2) or (medicin* adj3 plant$1) or (botanical* adj3 medicin*) or (botanical* adj3 drug$1) or (herb$2 adj3 drug$1) or (therapeutic* adj3 herb$2) or (therapeutic* adj3 plant$1) or (therapeutic* adj3 botanical*) or (plant$1 adj3 pharmacotherap*) or (plant$1 adj3 pharmaco-therap*) or (herb$2 adj3 pharmacotherap*) or (herb$2 adj3 pharmaco-therap*) or (botanical adj3 pharmacotherap*) or (botanical adj3 pharmaco-therap*) or (Chinese adj2 medicin*) or (Chinese adj2 medicin*) or (Chinese adj2 drug$1) or (Chinese adj2 pharmacotherap*) or (Chinese adj2 pharmaco-therap*) or phytochemical* or phyto-chemical* or phytonutrient* or phyto-nutrient* or phytotherap* or phyto-therap* or phytomedicin* or phyto-medicin*).ti,ab.
11. exp Folic Acid/
12. (folic acid$1 or folacin or folate or folvite or pteroylglutamic acid or "Vitamin M").ti,ab.
13. Glucosamin*.ti,ab.
14. exp Salvia/
15. (salvia miltiorrhiza or danshen or horse-racing grass$2 or rat-tail grass$2 or red-rooted sage$1 or red root$1 or red sage$1 or red sage root or (root$1 adj3 purple sage$1) or scarlet sage$1).ti,ab.
16. (Ch'ih shen or Chinese Salvia or dangshem or dan shen or dan-shen or danshensu or fufangdenshen or huang ken or hung ken or pin-ma ts'ao or Radix salviae miltiorrhizae or Salvia bowelyana or Salvia miltiorrhiza or Salvia przewalskii or Salvia root$1 or Salvia yunnanensis or sh'ih shen or shu-wei ts'ao or tan seng or tan-shen or tzu tan-ken or yunzhi-danshen).ti,ab.
17. (Forskolin or Coleus forskohlii or Indian Coleus or Coleonol).ti,ab.
18. (ruscus or (butcher$2 adj broom$1)).ti,ab.
19. exp Cinnamomum/ or (Cinnamomum or Cinnamon*).ti,ab.
20. exp Taraxacum/ or (Taraxacum or dandelion* or blowball$1 or Irish daisy or Irish daisies or (pee adj3 bed) or (lion* adj2 tooth) or (lion* adj2 teeth) or (priest* adj2 crown$1)).ti,ab.
21. ((Dent adj2 lion$1) or huang hua di ding or yellow flower earth nail$1 or puffball$1 or swine snout$1).ti,ab.
22. exp Lycium/ or (lycium or wolfberr* or wolf berr* or gojiberr* or goji berr*).ti,ab.
23. exp Echinacea/ or (Echinacea or American coneflower$1 or purple coneflower$1 or Rudbeckia purpurea or Black Sampson or combflower$1 or Kansas snake root$1 or scurvy root$1).ti,ab.
24. exp Mentha piperita/ or exp Glycyrrhiza/ or (mentha piperita or peppermint$1 or glycyrrhiza or licorice$1 or liquorice$1).ti,ab.
25. exp Tanacetum parthenium/ or (Tanacetum parthenium or feverfew or (bachelor'* adj button$1) or featherfew or febrifuge plant$1 or featherfoil or tinospora or guduchi).ti,ab.
26. Chrysanthemum parthenium.ti,ab.
27. exp Allium sativum/
28. (garlic or allium or (nectar adj2 god$1) or pa-se-waa or poor man's treacle or stinking rose$1).ti,ab.
29. exp Ginkgo biloba/
30. (Ginkgo or Ginkgophyta or Maidenhair Tree$1 or Maiden Hair Tree$1 or Fossil Tree$1 or Duckfoot tree$1 or Duck foot tree$1 or Japanese silver apricot$1 or kew tree$1 or silver apricot$1).ti,ab.
31. exp Panax/
32. (Panax or Ginseng or Jen Shen or Ninjin or Renshen or Schinseng or Shinseng).ti,ab.
33. (Guggulipid$1 or guggul$1 or gugulipid$1 or gugulu or gugululipid$1 or guggulsterone$1 or yogaraj-guggulu).ti,ab.
34. (mukul or myrrh).ti,ab.
35. (((Gymnema or Periploca) adj3 wood$1) or small Indian ipecac or vishani or Sarpadarushtrika or Wakandi).ti,ab.
36. (hawthorn$2 or Crataegus oxycantha or (bread adj2 cheese tree$1) or cockspur thorn$1 or Chinese hawthorn$2 or May bush$2 or May tree$1 or May blossom$1 or May flower$1 or mayflower$1 or quickset or thorn-apple tree$1 or thornapple tree$1 or white thorn$1 or whitethorn$1).ti,ab.
37. (Convallaria or (lily adj3 valley) or lady$2 tears or ladies tears or may lily or may lilies or may bell$1 or maybell$1 or conval lily or conval lilies or lily constancy or (ladder$1 adj2 heaven) or male lily or male lilies).ti,ab.
38. exp Leonurus/
39. (Motherwort* or Leonorus cardiaca or lion$2 tail$1 or lion$2 ear$1 or throwwort*).ti,ab.
40. exp Milk thistle/
41. (Milk Thistle$1 or Silybum marianum or Carduus marianus or Holy thistle$1 or marythistle$1 or Mary$2 thistle$1 or Marian$2 thistle$1).ti,ab.
42. (Rauwolfia or Rauvolfia or Indian snakeroot$1 or Sarpa-gandha or Nakuli or Chota-chand or Kanakachandrika).ti,ab.
43. (red yeast rice extract* or Monascus purpureus or (mould species adj3 rice$1) or (red adj2 yeast$1) or (red adj2 rice$1) or red koji or red leaven$1).ti,ab.
44. exp eleutherococcus senticosus/
45. (Eleutherococcus or Siberian ginseng or Ci wu ju or Eleuthero or "touch-me-not" or "touch-me-nots" or devil$2 shrub$1).ti,ab.
46. ((Thorny bearer adj2 free) or ussurian thorny pepperbrush$2 or ussurian thorny pepper brush$2).ti,ab.
47. exp Hypericum/
48. (Hypericum or John$2 wort$1 or Johnswort$1 or Amber or (touch adj2 heal) or goat weed$1 or Hardhay$1 or Klamath weed$1 or Rosin rose$1 or Tipton weed$1 or (balm adj2 warrior$1)).ti,ab.
49. (Devil$2 scorge$1 or goatweed$1 or klammath weed$1).ti,ab.
50. exp Curcuma/
51. (Turmeric or curcuma or Indian saffron or Indian yellow root$1 or Zedoary zedoaria).ti,ab.
52. (Valerian* or vandal root$1 or all-heal$1 or setwall$1).ti,ab.
53. Selenoprotein$1.ti,ab.
54. (thioctic acid$1 or Alpha lipoic acid$1 or Alpha-Lipogamma or Alpha-Lipon Stada or alpha-Liponaure Heumann or Alpha-Liponsaure or Alpha-Lippon or alpha-Vibolex or Alphaflam).ti,ab.
55. ("Coenzyme Q10" or "CoQ 10" or CoQ10 or idebenone or ubiquinone or ubidecarenone or ubisemiquinone or "vitamin q10").ti,ab.
56. exp Fish Oils/
57. (fish adj2 oil$1).ti,ab.
58. ("omega 3" or "omega 3s" or omega three$1 or "n-3 Fatty Acid" or "n-3 Fatty Acids" or "n3 Fatty Acid" or "n3 Fatty Acids" or "n-3 Polyunsaturated Fatty Acid" or "n-3 Polyunsaturated Fatty Acids" or "n3 Polyunsaturated Fatty Acid" or "n3 Polyunsaturated Fatty Acids" or "n-3 PUFA" or "n3 PUFA").ti,ab.
59. (Eicosapentanoic acid$1 or decosahexanoic acid$1 or alpha linoleic acid$1).ti,ab.
60. (green tea$1 or black tea$1 or Camellia sinensis or Japanese tea$1 or Matsu-cha tea$1).ti,ab.
61. (Phytosterol$1 or Plant sterol$1 or Plant stanol$1 or Beta-sitosterol$1 or sterolin$1).ti,ab.
62. beta-Glucan$1.ti,ab.
63. exp Kava/
64. (kava or kawa or Piper methysticum).ti,ab.
65. (Psyllium or Plantago ovata or flea seed$1 or fleawort or hemicelluloses or plantago seed$1 or ispaghula husk$1 or ispagula husk$1 or ispaghula seed$1 or ispagula seed$1 or Plantago arenaria or Plantago isphagula or Plantago ispagula).ti,ab.
66. exp soy foods/
67. (soy or miso or natto or tempeh or tofu).ti,ab.
68. (Arginine or L-Arginine).ti,ab.
69. (Chia or Salvia columbariae or Salvia hispanica or salba).ti,ab.
70. (Chitin or chitosan or "N-carboxybutyl" or Poliglusam).ti,ab.
71. exp Cynara/
72. (Cynara or globe artichoke$1 or cardoon$1).ti,ab.
73. exp Carnitine/
74. (Carnitine or Bicarnesine or "L-Carnitine" or Levocarnitine or "Vitamin BT" or "Acetyl-L-carnitine" or carnitene or carnitor or canitor or "D-carnitine" or "D,L-carnitine" or "L-acetyl-carnitine" or "L-carnitina" or "L-carnitine" or "L-tartrate" or "L-CARNIPURE" or levacecarnine or levocarnitine or "L-propionylcarnitine" or "propionil-L-carnitine" or "propionyl-L-carnitine" or ST261).ti,ab.
75. (Pantethine or "Vitamin B5" or bile acid sequestrant$1 or cyproheptadine or cysteamine or "D-pantethine" or pantetheine or pantetheinase or Pantetina or panthenol or pantomin or pantosin or pantothenic acid$1 or sulfopantetheine).ti,ab.
76. (Policosanol$1 or D003 or hexacontanol$1 or isopolicosanol$1 or "Octa-60" or octacosanoic acid$1 or octacosanol$1 or ricewax$2 or winteriser cake$1 or winterizer cake$1 or sugar cane policosanol$1 or sunflower seed policosanol$1 or triacontanol$1 or wheat germ policosanol$1).ti,ab.
77. exp Withania/
78. (Withania or Ashwaganda or Indian ginseng or winter cherry or winter cherries or wintercherry or wintercherries or Ayurvedic ginseng).ti,ab.
79. exp Aloe/ or (aesculus or buckeye$1 or horse chestnut$1 or conqueror tree$1 or aloe vera or aloe barbadensis).ti,ab.
80. (ginger or Zingiber officinale or Gamma oryzanol).ti,ab.
81. exp Ephedra/ or exp Trigonella/ or (ephedra or trigonella or fenugreek or foenumgraecum or poenumgraecum).ti,ab.
82. (Gamma oryzanol or dong quai or tetrandrine or tetradrine or hanjisong).ti,ab.
83. exp Hydrastis/
84. (hydrastis or Golden Seal or Goldenseal).ti,ab.
85. or/7–84
86. ((functional adj food$1) or (therapeutic* adj food$1)).ti,ab.
87. ((Citrus adj paradisi) or (Vaccinium adj macrocarpon) or Viburnum or Punicaceae or blueberr* or cranberr* or grapefruit* or Toronja* or pomegranate* or (Punica adj granatum) or (bitter adj orange) or (citrus adj auranticum) or kijitsu or (shangzhou adj zhiqiao) or (zhi adj shi)).ti,ab.
88. exp beverages/ or (beverage* or drink* or juice* or tea or teas).ti,ab.
89. 87 and 88
90. exp Plant oils/
91. exp Olea/
92. ((botanic* or plant or plants or vegetable* or clove or cloves or corn or corns or cottonseed* or croton* or olive or olives or safflower* or sesame* or soybean* or teatree*) and (oil or oils)).ti,ab.
93. (Linaceae or flax or flaxseed* or Linum or linseed*).ti,ab.
94. exp Dietary fiber/
95. ((diet or diets or dietary) and (fibre or fibres or fiber or fibers or roughage or (wheat adj bran) or cereal*)).ti,ab.
96. exp Caffeine/ or caffein*.ti,ab.
97. (or/89–96) or 85 or 86
98. exp cardiovascular disease/ and exp drug therapy/
99. (Adrenergic adj2 Antagonist*).ti,ab.
100. ((beta adj1 Adrenergic adj2 block*) or beta block*).ti,ab.
101. (acebutolol or acebutalol or Apo-Acebutolol or Apo-Acebulalol or Sectral or Prent).ti,ab.
102. (betaxolol or Kerlon or Kerlone).ti,ab.
103. (bisoprolol or Concor or Concore or Zebeta or Monocor).ti,ab.
104. (carvedilol or Apo-carvedilol or Coreg or Dilatrend or Eucardic or Kredex).ti,ab.
105. (labetalol or Labetolol or Normodyne or Trandate).ti,ab.
106. (metoprolol or Betaloc or Betalok or Lopressor or Seloken).ti,ab.
107. (nadolol or Corgard or Solgol).ti,ab.
108. (nebivolol or Nebilet or Silostar).ti,ab.
109. (pindolol or Visken).ti,ab.
110. (propranolol or Avlocardyl or Deralin or Dociton or Inderal or Obsidan).ti,ab.
111. (sotalol or Darob).ti,ab.
112. (timolol or Blocadren).ti,ab.
113. exp Calcium channel blockers/
114. ((calcium block* adj2 exogenous) or (calcium antagonist* adj2 exogenous) or (calcium inhibitor* adj2 exogenous) or calcium channel block*).ti,ab.
115. (Dihydropyridine or Lemildipine).ti,ab.
116. (amlodipine or Norvasc or Istin).ti,ab.
117. (felodipine or Plendil or Renedil).ti,ab.
118. (isradipine or DynaCirc or Lomir or Prescal).ti,ab.
119. (nicardipine or Cardene).ti,ab.
120. (nifedipine or Adalat or Cordipin or Nifediac or Nifedical or Procardia).ti,ab.
121. (nimodipine or Nimotop).ti,ab.
122. (nisoldipine or Sular).ti,ab.
123. (diltiazem or Cardizem or Dilacor or Dilzem or Tiazac).ti,ab.
124. (verapamil or Bosoptin or Calan or Cordilox or Covera-HS or Isoptin or Iproveratril or Verelan).ti,ab.
125. exp enzyme inhibitors/
126. ((Angiotensin-Converting Enzyme adj1 Inhibitor*) or ACE inhibitor* or (Angiotensin-Converting Enzyme adj1 antagonist*)).ti,ab.
127. (dipeptidyl carboxypeptidase inhibitor* or (Kininase II adj2 inhibitor*) or (Kininase II adj2 antagonist*)).ti,ab.
128. (benazepril or Cibacen or Lotensin).ti,ab.
129. (captopril or Capoten or Lopirin).ti,ab.
130. (enalapril or Renitec or Renitek or Vasotec).ti,ab.
131. (fosinopril or Dynacil or Fozitec or Monopril or Staril or Tensocardil).ti,ab.
132. (lisinopril or Lysinopril or Prinivil or Zestril).ti,ab.
133. (moexipril or Perdix or Univasc).ti,ab.
134. (perindopril or Aceon or Coversyl or Prestarium).ti,ab.
135. (Quinapril or Accupril).ti,ab.
136. (Ramipril or Acovil or Altace or Triatec or Tritace or Vesdil).ti,ab.
137. (Trandolapril or Gopten or Mavik or Odrik).ti,ab.
138. (Candesartan or Atacand).ti,ab.
139. (eprosartan or Teveten).ti,ab.
140. (irbesartan or Aprovel or Avapro or Karvea).ti,ab.
141. (losartan or Cozaar).ti,ab.
142. (olmesartan or Benicar).ti,ab.
143. (telmisartan or Micardis or Pritor).ti,ab.
144. (valsartan or Diovan).ti,ab.
145. ((Renin adj Inhibit*) or Renin antagonist*).ti,ab.
146. (Aliskiren or Tekturna).ti,ab.
147. aldosterone receptor antagonist$1.ti,ab.
148. (Eplerenone or Inspra).ti,ab.
149. (Spironolactone or Aldactone or Verospirone).ti,ab.
150. exp Vasodilator agents/
151. Vasodilator$1.ti,ab.
152. exp Clonidine/
153. (clonidine or Apo-Clonidine or Catapres or Duraclon).ti,ab.
154. (guanabenz or Wytensin).ti,ab.
155. (guanfacine or Intuniv or Tenex).ti,ab.
156. (Methyldopa or Apo-Methyldopa or Aldoril or Aldomet or Dopamet or Dopegyt).ti,ab.
157. (Diazoxide or Hyperstat or Proglycem).ti,ab.
158. (Hydralazine or Apo-Hydralazine or Apresoline or Dralzine).ti,ab.
159. (minoxidil or Loniten).ti,ab.
160. (Isosorbide Dinitrate or Dilatrate or Cedocard or Isoket or Isotrate or Isordil or Sorbitrate).ti,ab.
161. (nitroglycerin$1 or Natispray or Nitro-Dur or Nitromist or Nitrospan or Nitrostat or Nitro-Time or Transderm Nitro or Tridil or Trinipatch).ti,ab.
162. ((Phosphodiesterase adj1 Inhibit*) or (Phosphodiesterase adj1 antagonist*) or Antiphosphodiesterase$1 or Anti-phosphodiesterase$1 or (Phosphoric Diester Hydrolase adj1 Inhibit*) or (Phosphoric Diester Hydrolase adj1 antagonist*)).ti,ab.
163. (sildenafil or Revatio or tadalafil or vardenafil).ti,ab.
164. (Cilostazol or Pletal).ti,ab.
165. Alprostadil.ti,ab.
166. (Epoprostenol or Flolan).ti,ab.
167. (iloprost or Ciloprost or Ventavis).ti,ab.
168. (Endothelin antagonist$1 or (Endothelin adj1 inhibit*)).ti,ab.
169. (treprostinil or Remodulin or bosentan or Tracleer or ambrisentan or Letairis).ti,ab.
170. papaverine.ti,ab.
171. (isoxsuprine or Duvadilan).ti,ab.
172. ((alpha-Adrenergic adj2 block*) or (Adrenergic alpha adj2 block*) or (alpha-Adrenergic adj2 antagonist*) or (Adrenergic alpha adj2 antagonist*) or (alpha block* adj2 adrenergic) or (alpha antagonist* adj2 adrenergic)).ti,ab.
173. (doxazosin or Cardura or Carduran or Diblocin or Doxazomerck or Doxazosin or Progandol).ti,ab.
174. (prazosin or Minipress or Furazosin or Pratsiol).ti,ab.
175. (terazosin or Adecur or Apo-Terazosin or Deflox or Dysalfa or Flotrin or Heitrin or Hytrin or Hytrine or Magnurol).ti,ab.
176. ((Anti-Arrhythmia or Anti-Arrhythmic* or Antiarrhythmia or Antiarrhythmic* or Anti-fibrillatory or Antifibrillatory) and (drug or drugs or agent or agents or medication* or prescription*)).ti,ab.
177. (disopyramide or Norpace or Rhythmodan).ti,ab.
178. (procainamide or Apo-Procainamide or Biocoryl or Novocainamide or Novocamid or Procamide or Pronestyl or Procan or Procanbid).ti,ab.
179. (quinidine or Apo-Quinidine or Chinidin or Quinidex or Quinora).ti,ab.
180. Mexiletine.ti,ab.
181. (encainide or Enkaid).ti,ab.
182. (Flecainide or Tambocor).ti,ab.
183. (propafenone or Apo-Propafenone or Arythmol or Baxarytmon or Fenoprain or Rythmol or Rytmonorm).ti,ab.
184. (amiodarone or Amiodarona or Cordarone or Cordarex or Pacerone or Trangorex).ti,ab.
185. (dofetilide or Tikosyn).ti,ab.
186. (dronedarone or Multaq).ti,ab.
187. exp Cardiotonic agents/
188. ((Cardiotonic or Cardioprotective or Cardio-tonic or Cardio-protective) and (drug or drugs or agent or agents or medication$1 or prescription$1)).ti,ab.
189. (cardiotonics or cardio-tonics or cardiac stimulant* or myocardial stimulant* or inotropic agent*).ti,ab.
190. exp Digoxin/
191. (digoxin or Digacin or Digitek or Dilanacin or Lanacordin or Lanicor or Lanoxicaps or Lanoxin or Lenoxin).ti,ab.
192. exp Antilipemic agents/
193. (Antilipemic$1 or anti-lipemic$1 or hypolipidemic$1 or hypo-lipidemic$1).ti,ab.
194. ((Antilipemic or anti-lipemic or antihyperlipemic or anti-hyperlipemic or antihyperlipidemic or anti-hyperlipidemic or hypolipidemic or hypo-lipidemic) and (drug or drugs or agent or agents or medication* or prescription*)).ti,ab.
195. (antihyperlipemics or anti-hyperlipemics or antihyperlipidemics or anti-hyperlipidemics).ti,ab.
196. (cholestyramin$1 or colestyramin$1 or Cuemid or Quantalan or Questran).ti,ab.
197. (colestipol or Colestid).ti,ab.
198. (colesevelam or CholestaGel or Welchol).ti,ab.
199. (Bile acid sequestrant$1 or bile acid-binding drug$1 or bile acid-binding agent$1).ti,ab.
200. (Anticholesteremic$1 or Hypocholesteremic$1 or (cholesterol adj2 inhibitor$1) or cholesterol-lowering drug$1 or cholesterol-lowering agent$1 or cholesterol-lowering medication$1).ti,ab.
201. (ezetimibe or Zetia).ti,ab.
202. (fenofibrate or Antara or Fenoglide or Fibricor or Lipofen or Lofibra or TriCor or Triglide or Trilipix).ti,ab.
203. (Gemfibrozil or Apo-Gemfibrozil or Lopid or Trialmin).ti,ab.
204. ((Hydroxymethylglutaryl-CoA Reductase adj1 inhibit*) or (HMG-CoA Reductase adj1 inhibit*) or (Hydroxymethylglutaryl-CoA adj1 inhibit$) or (Hydroxymethylglutaryl-Coenzyme A adj1 inhibit$)).ti,ab.
205. (atorvastatin or Liptor).ti,ab.
206. (fluvastatin or Lescol).ti,ab.
207. (lovastatin or Altocor or Altoprev or Mevacor).ti,ab.
208. (pravastatin or Apo-Pravastatin or Lipostat or Pravasin$1 or Pravachol or Selektine).ti,ab.
209. (rosuvastatin or Crestor).ti,ab.
210. (simvastatin or Synvinolin or Zocor).ti,ab.
211. exp Niacin/
212. (niacin or Niacor or Niaspan or Nicobid or Nicolar or Nicotinex or Slo-Niacin).ti,ab.
213. exp Anticoagulants/
214. (Anticoagulant$1 or anti-coagulant$1 or bloodthinn* or blood-thinn*).ti,ab.
215. (warfarin or Apo-Warfarin or Coumadin$1).ti,ab.
216. (dalteparin or Fragmin$1).ti,ab.
217. exp Heparin/
218. heparin.ti,ab.
219. (tinzaparin or Innohep).ti,ab.
220. (antithrombocytic* or anti-thrombocytic* or (platelet$1 adj2 inhibit*) or Antiplatelet$1 or Anti-platelet$1 or Platelet Antagonist$1 or Platelet Antiaggregant$1).ti,ab.
221. exp Aspirin/
222. (Aspirin or Acetylsalicylic or Acylpyrin or Aloxiprimum or Aspergum or Bufferin or Colfarit or Dispril or Ecotrin or Easprin or Endosprin or Magnecyl or Micristin or Polopirin or Polopiryna or Solprin or Solupsan or Zorprin).ti,ab.
223. (ticlopidine or Ticlid).ti,ab.
224. (clopidogrel or Plavix).ti,ab.
225. exp Diuretics/
226. (diuretic$1 or water pill$1).ti,ab.
227. (Bumetanide or bumex).ti,ab.
228. (etacrynic acid or ethacrynic acid or Edecrin).ti,ab.
229. (furosemide or Errolon or Fursemide or Fusid or Lasix).ti,ab.
230. (torsemide or Demadex or torasemide).ti,ab.
231. (k-sparing or potassium-sparing).ti,ab.
232. (Amiloride or Amidal or Amiduret or Kaluril or Midamor or Midoride or Modamide).ti,ab.
233. (triamterene or Dyrenium).ti,ab.
234. thiazide diuretic$1.ti,ab.
235. (Bendroflumethiazide or Bendrofluazide).ti,ab.
236. (chlorothiazide or Chlotride or Diuril).ti,ab.
237. (hydrochlorothiazide or Apo-Hydro or Dichlotride or Esidrex or HydroDIURIL or Microzide or Oretic).ti,ab.
238. (methyclothiazide or Aquatensen or Enduron).ti,ab.
239. (polythiazide or Renese).ti,ab.
240. (chlorthalidone or Apo-Chlorthalidone or Hygroton or Thalitone).ti,ab.
241. (indapamide or Lozol or Metindamide).ti,ab.
242. (metolazone or Mykrox or Zaroxolyn or Zytanix).ti,ab.
243. or/98–242
244. 97 and 243
245. exp Herb drug interactions/
246. (interact* or react* or contraindicat* or contra-indicat* or chemically induce* or enhance* or potentiat* or synergis* or toxic or toxicit*).ti,ab.
247. 245 or 246
248. 244 and 247
249. meta analysis/
250. meta analysis.pt.
251. (meta-analy* or metanaly* or metaanaly* or met analy* or integrative research or integrative review* or integrative overview* or research integration or research overview* or collaborative review*).ti,ab.
252. (systematic review* or systematic overview* or technology assessment* or HTA or HTAs).ti,ab.
253. health technol assess rep.ja.
254. evid rep technol assess summ.ja.
255. or/249–254
256. 248 and 255
257. (controlled clinical trial or controlled trial or randomised controlled trial or randomized controlled trial).pt.
258. exp Randomized controlled trials/
259. exp Random allocation/
260. exp Double blind method/
261. exp Placebos/
262. (random* or RCT$1 or placebo*).ti,ab.
263. ((singl* or doubl* or trebl* or tripl*) and (mask* or blind* or dumm*)).ti,ab.
264. controlled clinical trial.ti,ab.
265. or/257–264
266. 248 and 265
267. 266 not 256
268. clinical trial.pt.
269. exp Clinical trials/
270. "clinical trial".ti,ab.
271. (comparative studies or comparative study or evaluation studies or multicenter study or multicentre study).pt.
272. (volunteer or volunteers or open label* or nonrandom* or non random* or quasirandom* or quasi-random*).ti,ab.
273. exp cohort studies/ or exp longitudinal studies/ or exp prospective studies/ or exp Follow up studies/ or exp retrospective studies/ or exp case control studies/ or exp Comparative study/
274. (cohort or cohorts or longitudinal or prospective or retrospective).ti,ab.
275. ((observational or follow-up or followup) adj stud*).ti,ab.
276. (population-based stud* or population-based analys* or population stud* or population analys*).ti,ab.
277. ((descriptive adj stud*) or (multidimensional adj stud*) or (multi-dimensional adj stud*) or (multicenter adj stud*) or (multi-center adj stud*) or (multicentr* adj stud*) or (multi-centr* adj stud*)).ti,ab.
278. ((comparative adj study) or (comparative adj studies) or (case adj control*) or "case series" or (case adj comparison*) or (case adj history) or (case adj histories)).ti,ab.
279. or/268–278
280. 248 and 279
281. 280 not (256 or 266)
282. exp Mortality/ or exp Risk/ or exp Morbidity/
283. exp Adverse effects/ or exp Safety/ or exp Complications/
284. (adverse or complication* or harm or harms or harmful or harming or injurious or morbidit* or mortalit* or risk$1 or side effect$1 or undersirable or tolerability or teratogen* or safety).ti,ab.
285. or/282–284
286. 248 and 285
287. 286 not (256 or 266 or 280)

## EMBASE (September 1, 2011)

1. exp diet supplementation/
2. exp cardiovascular agent/
3. 1 and 2
4. 3
5. limit 4 to human

## Cochrane Library (September 1, 2011)

#1 MeSH descriptor Herb-Drug Interactions explode all trees
#2 ((herb or herbs or herbal or plant or plants or botanic*) and (drug or drugs or medication* or prescription* or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)):ti,ab,kw
#3 MeSH descriptor Food-Drug Interactions explode all trees
#4 ((food or foods) and (drug or drugs or medication* or prescription* or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)):ti,ab,kw
#5 (#1 OR #2 OR #3 OR #4)
#6 MeSH descriptor Dietary Supplements explode all trees
#7 (Neutraceutical* or Nutraceutical* or (diet* NEXT supplement*) or (nutrition* NEXT supplement*) or (food* NEXT supplement*) or (mineral* NEXT supplement*) or (vitamin* NEXT supplement*) or (botanic* NEXT supplement*)):ti,ab,kw
#8 MeSH descriptor Vitamins explode all trees
#9 (vitamin or vitamins ):ti,ab,kw or (folic acid):ti,ab,kw
#10 MeSH descriptor Minerals explode all trees
#11 MeSH descriptor Copper explode all trees
#12 MeSH descriptor Iron explode all trees
#13 MeSH descriptor Magnesium explode all trees
#14 MeSH descriptor Potassium explode all trees
#15 MeSH descriptor Selenium explode all trees
#16 (copper or iron or magnesium or potassium or selenium):ti,ab,kw
#17 MeSH descriptor Plant Preparations explode all trees
#18 MeSH descriptor Plant Extracts explode all trees
#19 MeSH descriptor Drugs, Chinese Herbal explode all trees
#20 MeSH descriptor Plants, Medicinal explode all trees
#21 ((medicin* NEAR/3 herb*) or (medicin* NEAR/3 plant*) or (botanical* NEAR/3 medicin*) or (botanical* NEAR/3 drug*) or (herb* NEAR/3 drug*) or (therapeutic* NEAR/3 herb*) or (therapeutic* NEAR/3 plant*) or (therapeutic* NEAR/3 botanical*) or (plant* NEAR/3 pharmacotherap*) or (plant* NEAR/3 pharmaco-therap*)):ti,ab,kw or ((herb* NEAR/3 pharmacotherap*) or (herb* NEAR/3 pharmaco-therap*) or (botanical NEAR/3 pharmacotherap*) or (botanical NEAR/3 pharmaco-therap*) or (Chinese NEAR/2 medicin*) or (Chinese NEAR/2 medicin*) or (Chinese NEAR/2 drug*) or (Chinese NEAR/2 pharmacotherap*) or (Chinese NEAR/2 pharmaco-therap*)):ti,ab,kw or (phytochemical* OR phyto-chemical* OR phytonutrient* OR phyto-nutrient*):ti,ab,kw
#22 MeSH descriptor Glucosamine explode all trees
#23 (glucosamin*):ti,ab,kw
#24 MeSH descriptor Salvia miltiorrhiza explode all trees
#25 (salvia miltiorrhiza or danshen or horse-racing grass* or rat-tail grass* or red-rooted sage* or red root* or red sage* or red sage root or (root* NEAR/3 purple sage*) or scarlet sage*):ti,ab,kw or (Ch'ih shen or Chinese Salvia or dangshem or dan shen or dan-shen or danshensu or fufangdenshen or huang ken or hung ken or pin-ma ts'ao or Radix salviae miltiorrhizae or Salvia bowelyana or Salvia miltiorrhiza or Salvia przewalskii or Salvia root* or Salvia yunnanensis or sh'ih shen or shu-wei ts'ao or tan seng or tan-shen or tzu tan-ken or yunzhi-danshen):ti,ab,kw
#26 MeSH descriptor Forskolin explode all trees
#27 MeSH descriptor Ruscus explode all trees
#28 MeSH descriptor Cinnamomum zeylanicum explode all trees
#29 (Forskolin or Coleus forskohlii or Indian Coleus or Coleonol):ti,ab,kw or (ruscus or (butcher* NEXT broom*)):ti,ab,kw or (Cinnamomum or Cinnamon*):ti,ab,kw
#30 MeSH descriptor Taraxacum explode all trees
#31 (Taraxacum or dandelion* or blowball* or Irish daisy or Irish daisies or (pee NEAR/3 bed) or (lion* NEAR/2 tooth) or (lion* NEAR/2 teeth) or (priest* NEAR/2 crown*)):ti,ab,kw or (Dent NEAR/2 lion*) or huang hua di ding or yellow flower earth nail* or puffball* or swine snout*:ti,ab,kw
#32 MeSH descriptor Echinacea explode all trees
#33 (Echinacea or American coneflower* or purple coneflower* or Rudbeckia purpurea or Black Sampson or combflower* or Kansas snake root* or scurvy root*):ti,ab,kw
#34 MeSH descriptor Tanacetum parthenium explode all trees
#35 (Tanacetum parthenium or feverfew or (bachelor* NEXT button*) or featherfew or febrifuge plant* or featherfoil*):ti,ab,kw or (Chrysanthemum parthenium):ti,ab,kw
#36 MeSH descriptor Garlic explode all trees
#37 (garlic or allium or (nectar NEAR/2 god*) or pa-se-waa or poor man's treacle or stinking rose*):ti,ab,kw
#38 MeSH descriptor Ginkgo biloba explode all trees
#39 (Ginkgo or Ginkgophyta or Maidenhair Tree* or Maiden Hair Tree* or Fossil Tree* or Duckfoot tree* or Duck foot tree* or silver apricot* or kew tree*):ti,ab,kw
#40 MeSH descriptor Panax explode all trees
#41 (Panax or Ginseng or Jen Shen or Ninjin or Renshen or Schinseng or Shinseng):ti,ab,kw or (guggulipid* or guggul* or gugulipid* or gugulu or gugululipid* or guggulsterone* or yogaraj-guggulu):ti,ab,kw
#42 MeSH descriptor Lycium explode all trees
#43 (wolfberr* or (wolf NEXT berr*) or gojiberr* or (goji NEXT berr*)):ti,ab,kw
#44 MeSH descriptor Mentha piperita explode all trees
#45 MeSH descriptor Glycyrrhiza explode all trees
#46 MeSH descriptor Tinospora explode all trees
#47 (Chrysanthemum parthenium or gynura or gynuras or gulvel or gulvels):ti,ab,kw
#48 MeSH descriptor Gymnema explode all trees
#49 (Gymnema or (Periploca NEAR/3 wood*) or small Indian ipecac or vishani or Sarpadarushtrika or Wakandi):ti,ab,kw or (hawthorn* or Crataegus oxycantha or (bread NEAR/2 cheese tree*) or cockspur thorn* or Chinese hawthorn* or May bush* or May tree* or May blossom* or May flower* or mayflower* or quickset or thorn-apple tree* or thornapple tree* or white thorn* or whitethorn*):ti,ab,kw
#50 MeSH descriptor Convallaria explode all trees
#51 (Convallaria or (lily NEAR/3 valley) or (lady* NEXT tears) or ladies tears or may lily or may lilies or may bell or may bells or maybell* or conval lily or conval lilies or lily constancy or (ladder* NEAR/2 heaven) or male lily or male lilies):ti,ab,kw
#52 MeSH descriptor Leonurus explode all trees
#53 (Motherwort* or Leonorus cardiaca or (lion* NEXT tail*) or (lion* NEXT ear*) or throwwort*):ti,ab,kw
#54 MeSH descriptor Milk Thistle explode all trees
#55 (Milk Thistle* or Silybum marianum or Carduus marianus or Holy thistle* or marythistle* or (Mary* NEXT thistle*) or (Marian* NEXT thistle*)):ti,ab,kw
#56 MeSH descriptor Rauwolfia explode all trees
#57 (Rauwolfia or Rauvolfia or Indian snakeroot* or Sarpa-gandha or Nakuli or Chota-chand or Kanakachandrika):ti,ab,kw or (red yeast rice extract* or Monascus purpureus or (mould species NEAR/3 rice*) or (red NEAR/2 yeast*) or (red NEAR/2 rice*) or red koji or red leaven*):ti,ab,kw
#58 MeSH descriptor Eleutherococcus explode all trees
#59 (Eleutherococcus or Siberian ginseng or Ci wu ju or Eleuthero or "touch-me-not" or "touch-me-nots" or (devil* NEXT shrub*)):ti,ab,kw or ((Thorny bearer NEAR/2 free) or ussurian thorny pepperbrush* or ussurian thorny pepper brush*):ti,ab,kw
#60 MeSH descriptor Hypericum explode all trees
#61 (Hypericum or (John* NEXT wort*) or Johnswort* or Amber or (touch NEAR/2 heal) or goat weed* or goatweed* or Hardhay* or Klamath weed* or Klammath weed* or Rosin rose* or Tipton weed* or (balm NEAR/2 warrior*) or (Devil* NEXTscorge*)):ti,ab,kw
#62 MeSH descriptor Curcuma explode all trees
#63 MeSH descriptor Valerian explode all trees
#64 (Turmeric or curcuma or Indian saffron or Indian yellow root* or Zedoary zedoaria):ti,ab,kw or (Valerian* or vandal root* or all-heal* or setwall*):ti,ab,kw
#65 MeSH descriptor Selenoproteins explode all trees
#66 MeSH descriptor Thioctic Acid explode all trees
#67 (Selenoprotein*):ti,ab,kw or (Alpha lipoic acid* or Alpha-Lipogamma or Alpha-Lipon Stada or alpha-Liponaure Heumann or Alpha-Liponsaure or Alpha-Lippon or alpha-Vibolex or Alphaflam):ti,ab,kw or “Coenzyme Q10” or “CoQ 10” or CoQ10 or idebenone or ubiquinone or ubidecarenone or ubisemiquinone or “vitamin q10”:ti,ab,kw
#68 MeSH descriptor Fish Oils explode all trees
#69 MeSH descriptor Fatty Acids, Omega-3 explode all trees
#70 (fish NEAR/2 oil) of (fish NEAR/2 oils):ti,ab,kw or (“omega 3” or “omega 3s” or omega three$1 or “n-3 Fatty Acid” or “n-3 Fatty Acids” or “n3 Fatty Acid” or “n3 Fatty Acids” or “n-3 Polyunsaturated Fatty Acid” or “n-3 Polyunsaturated Fatty Acids” or “n3 Polyunsaturated Fatty Acid” or “n3 Polyunsaturated Fatty Acids” or “n-3 PUFA” or “n3 PUFA”):ti,ab,kw
#71 (Eicosapentanoic acid* or decosahexanoic acid* or alpha linoleic acid*):ti,ab,kw or (green tea or green teas or black tea or black teas or Camellia sinensis or Japanese tea or Japanese teas or Matsu-cha tea or Matsu-cha teas):ti,ab,kw
#72 MeSH descriptor Phytosterols explode all trees
#73 MeSH descriptor beta-Glucans explode all trees
#74 (Phytosterol* or plant sterol* or plant stanol* or beta-sitosterol* or sterolin*):ti,ab,kw or (beta-Glucan or beta-Glucans):ti,ab,kw
#75 MeSH descriptor Calcium explode all trees
#76 MeSH descriptor Psyllium explode all trees
#77 (calcium or bone meal or dicalcium or dolomite):ti,ab,kw or (Psyllium or Plantago ovata or flea seed* or fleawort or hemicelluloses or plantago seed* or ispaghula husk* or ispaghula seed* or Plantago arenaria or Plantago isphagula):ti,ab,kw
#78 MeSH descriptor Soybeans explode all trees
#79 MeSH descriptor Arginine explode all trees
#80 (soy or soybean* or Glycine max):ti,ab,kw or (Arginine or L-Arginine):ti,ab,kw or (Chia or Salvia columbariae or Salvia hispanica or salba):ti,ab,kw
#81 MeSH descriptor Chitosan explode all trees
#82 MeSH descriptor Cynara explode all trees
#83 MeSH descriptor Carnitine explode all trees
#84 (Chitin or chitosan or “N-carboxybutyl” or Poliglusam):ti,ab,kw or (Cynara or globe artichoke* or cardoon*):ti,ab,kw or (Carnitine or Bicarnesine or “L-Carnitine” or Levocarnitine or “Vitamin BT” or “Acetyl-L-carnitine” or carnitene or carnitor or canitor or “D-carnitine” or “D,L-carnitine” or “L-acetyl-carnitine” or “L-carnitina” or “L-carnitine” or “L-tartrate” or “L-CARNIPURE” or levacecarnine or levocarnitine or “L-propionylcarnitine” or “propionil-L-carnitine” or “propionyl-L-carnitine” or ST261):ti,ab,kw
#85 (Pantethine or “Vitamin B5” or bile acid sequestrant* or cyproheptadine or cysteamine or “D-pantethine” or pantetheine or pantetheinase or Pantetina or panthenol or pantomin or pantosin or pantothenic acid* or sulfopantetheine):ti,ab,kw or (Policosanol* or D003 or hexacontanol* or isopolicosanol* or “Octa-60” or octacosanoic acid* or octacosanol* or ricewax* or winteriser cake* or winterizer cake* or sugar cane policosanol* or sunflower seed policosanol* or triacontanol* or wheat germ policosanol*):ti,ab,kw
#86 MeSH descriptor Withania explode all trees
#87 MeSH descriptor Aesculus explode all trees
#88 MeSH descriptor Aloe explode all trees
#89 (Withania or Ashwaganda or Indian ginseng or winter cherry or winter cherries or wintercherry or wintercherries or Ayurvedic ginseng):ti,ab,kw or (aesculus or buckeye* or horse chestnut* or conqueror tree* or aloe vera or aloe barbadensis):ti,ab,kw
#90 MeSH descriptor Ginger explode all trees
#91 MeSH descriptor Ephedra explode all trees
#92 MeSH descriptor Trigonella explode all trees
#93 (ginger or Zingiber officinale or Gamma oryzanol):ti,ab,kw or (ephedra or trigonella or fenugreek or foenumgraecum or poenumgraecum):ti,ab,kw or (Gamma oryzanol or dong quai or tetrandrine or tetradrine or hanjisong):ti,ab,kw
#94 (#8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18)
#95 (#22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50 OR #51 OR #52 OR #53 OR #54 OR #55 OR #56 OR #57 OR #58 OR #59 OR #60)
#96 (#61 OR #62 OR #63 OR #64 OR #65 OR #66 OR #67 OR #68 OR #69 OR ( #70 AND OF AND #71 ) OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 OR #78 OR #79 OR #80 OR #81 OR #82 OR #83 OR #84 OR #85 OR #86 OR #87 OR #88 OR #89 OR #90 OR #91 OR #92 OR #93)
#97 MeSH descriptor Phytotherapy explode all trees
#98 (phytotherap* or phyto-therap* or phytomedicin* or phyto-medicin*)
#99 MeSH descriptor Cardiovascular Diseases explode all trees with qualifier: DT
#100 Any MeSH descriptor with qualifier: TU
#101 (#97 OR #98 OR #99 OR #100)
#102 (#94 OR #95 OR #96)
#103 (#101 AND #102)
#104 (#6 OR #7 OR #19 OR #20 OR #21)
#105 (#103 OR #104)
#106 (#97 OR #98 OR #105)
#107 MeSH descriptor Functional Food explode all trees
#108 (functional NEXT food*) or (therapeutic* NEXT food*):ti,ab,kw
#109 MeSH descriptor Citrus paradisi explode all trees
#110 MeSH descriptor Vaccinium macrocarpon explode all trees
#111 MeSH descriptor Viburnum explode all trees
#112 MeSH descriptor Blueberry Plant explode all trees
#113 MeSH descriptor Punicaceae explode all trees
#114 (citrus paradisi or vaccinium macrocarpon or viburnum or punicaceae or blueberr* or cranberr* or grapefruit* or toronja* or pomegranate* or punica granatum or bitter orange or citrus uranticum or kijitsu or shangzhou zhiqiao or zhi shi):ti,ab,kw
#115 MeSH descriptor Beverages explode all trees
#116 (beverage* or drink* or juice* or tea or teas):ti,ab,kw
#117 (#109 OR #110 OR #111 OR #112 OR #113 OR #114)
#118 (#115 OR #116)
#119 (#117 AND #118)
#120 MeSH descriptor Plant Oils explode all trees
#121 MeSH descriptor Olea explode all trees
#122 (botanic* or plant or plants or vegetable* or clove or cloves or corn or corns or cottonseed* or croton* or olive or olives or safflower* or sesame* or soybean* or teatree*):ti,ab,kw and (oil or oils):ti,ab,kw
#123 MeSH descriptor Linaceae explode all trees
#124 (Linaceae or flax or flaxseed* or Linum or linseed*):ti,ab,kw
#125 MeSH descriptor Dietary Fiber explode all trees
#126 (diet or diets or dietary):ti,ab,kw and (fibre or fibres or fiber or fibers or roughage or (wheat NEXT bran) or cereal*):ti,ab,kw
#127 MeSH descriptor Caffeine explode all trees
#128 (#120 OR #121 OR #122 OR #123 OR #124 OR #125 OR #126 OR #127)
#129 (#107 OR #108 OR #119 OR #128)
#130 MeSH descriptor Cardiovascular Diseases explode all trees with qualifier: DT
#131 MeSH descriptor Adrenergic beta-Antagonists explode all trees
#132 MeSH descriptor Acebutolol explode all trees
#133 MeSH descriptor Betaxolol explode all trees
#134 MeSH descriptor Bisoprolol explode all trees
#135 (Adrenergic NEAR/2 Antagonist*) OR (beta NEXT block*) OR ((beta NEAR/1 Adrenergic) NEAR/2 block*):ti,ab,kw or (acebutolol or acebutalol or Apo-Acebutolol or Apo-Acebulalol or Sectral or Prent):ti,ab,kw or (betaxolol or Kerlon or Kerlone):ti,ab,kw or (bisoprolol or Concor or Concore or Zebeta or Monocor):ti,ab,kw or (carvedilol or Apo-carvedilol or Coreg or Dilatrend or Eucardic or Kredex):ti,ab,kw
#136 MeSH descriptor Labetalol explode all trees
#137 MeSH descriptor Metoprolol explode all trees
#138 MeSH descriptor Nadolol explode all trees
#139 MeSH descriptor Pindolol explode all trees
#140 MeSH descriptor Propranolol explode all trees
#141 (labetalol or Labetolol or Normodyne or Trandate):ti,ab,kw or (metoprolol or Betaloc or Betalok or Lopressor or Seloken):ti,ab,kw or (nadolol or Corgard or Solgol or nebivolol or Nebilet or Silostar):ti,ab,kw or (pindolol or Visken):ti,ab,kw or (propranolol or Avlocardyl or Deralin or Dociton or Inderal or Obsidan):ti,ab,kw
#142 MeSH descriptor Sotalol explode all trees
#143 MeSH descriptor Timolol explode all trees
#144 MeSH descriptor Calcium Channel Blockers explode all trees
#145 MeSH descriptor Amlodipine explode all trees
#146 (sotalol or Darob):ti,ab,kw or (timolol or Blocadren):ti,ab,kw or (calcium block* NEAR/2 exogenous) or (calcium antagonist* NEAR/2 exogenous) or (calcium inhibitor* NEAR/2 exogenous) or calcium channel block*:ti,ab,kw or (Dihydropyridine or Lemildipine):ti,ab,kw or (amlodipine or Norvasc or Istin):ti,ab,kw
#147 MeSH descriptor Felodipine explode all trees
#148 MeSH descriptor Isradipine explode all trees
#149 MeSH descriptor Nicardipine explode all trees
#150 MeSH descriptor Nifedipine explode all trees
#151 MeSH descriptor Nimodipine explode all trees
#152 (felodipine or Plendil or Renedil):ti,ab,kw or (isradipine or DynaCirc or Lomir or Prescal):ti,ab,kw or (nicardipine or Cardene):ti,ab,kw or (nifedipine or Adalat or Cordipin or Nifediac or Nifedical or Procardia):ti,ab,kw or (nimodipine or Nimotop):ti,ab,kw
#153 MeSH descriptor Nisoldipine explode all trees
#154 MeSH descriptor Diltiazem explode all trees
#155 MeSH descriptor Verapamil explode all trees
#156 (nisoldipine or Sular):ti,ab,kw or (diltiazem or Cardizem or Dilacor or Dilzem or Tiazac):ti,ab,kw or (verapamil or Bosoptin or Calan or Cordilox or Covera-HS or Isoptin or Iproveratril or Verelan):ti,ab,kw
#157 MeSH descriptor Angiotensin-Converting Enzyme Inhibitors explode all trees
#158 (Angiotensin-Converting Enzyme NEXT Inhibitor*) or ACE inhibitor* or (Angiotensin-Converting Enzyme antagonist*):ti,ab,kw or (Kininase II NEAR/2 inhibitor*) or (Kininase II NEAR/2 antagonist*):ti,ab,kw or (benazepril or Cibacen or Lotensin):ti,ab,kw
#159 MeSH descriptor Captopril explode all trees
#160 MeSH descriptor Enalapril explode all trees
#161 MeSH descriptor Fosinopril explode all trees
#162 MeSH descriptor Lisinopril explode all trees
#163 MeSH descriptor Perindopril explode all trees
#164 (captopril or Capoten or Lopirin):ti,ab,kw or (enalapril or Renitec or Renitek or Vasotec):ti,ab,kw or (fosinopril or Dynacil or Fozitec or Monopril or Staril or Tensocardil):ti,ab,kw or (lisinopril or Lysinopril or Prinivil or Zestril or moexipril or Perdix or Univasc):ti,ab,kw or (perindopril or Aceon or Coversyl or Prestarium or Quinapril or Accupril):ti,ab,kw
#165 MeSH descriptor Ramipril explode all trees
#166 MeSH descriptor Losartan explode all trees
#167 (Ramipril or Acovil or Altace or Triatec or Tritace or Vesdil):ti,ab,kw or (Trandolapril or Gopten or Mavik or Odrik or Candesartan or Atacand):ti,ab,kw or (eprosartan or Teveten or irbesartan or Aprovel or Avapro or Karvea):ti,ab,kw or (losartan or Cozaar or olmesartan or Benicar ):ti,ab,kw or (telmisartan or Micardis or Pritor or valsartan or Diovan):ti,ab,kw
#168 (renin NEXT inhibit*) or renin antagonist*:ti,ab,kw or (Aliskiren or Tekturna):ti,ab,kw or (aldosterone receptor antagonist*):ti,ab,kw or (Eplerenone or Inspra):ti,ab,kw
#169 MeSH descriptor Spironolactone explode all trees
#170 MeSH descriptor Vasodilator Agents explode all trees
#171 MeSH descriptor Clonidine explode all trees
#172 MeSH descriptor Guanabenz explode all trees
#173 MeSH descriptor Guanfacine explode all trees
#174 (Spironolactone or Aldactone or Verospirone):ti,ab,kw or (Vasodilator*):ti,ab,kw or (clonidine or Apo-Clonidine or Catapres or Duraclon):ti,ab,kw or (guanabenz or Wytensin):ti,ab,kw or (guanfacine or Intuniv or Tenex):ti,ab,kw
#175 MeSH descriptor Methyldopa explode all trees
#176 MeSH descriptor Diazoxide explode all trees
#177 MeSH descriptor Hydralazine explode all trees
#178 MeSH descriptor Minoxidil explode all trees
#179 MeSH descriptor Isosorbide Dinitrate explode all trees
#180 (Methyldopa or Apo-Methyldopa or Aldoril or Aldomet or Dopamet or Dopegyt):ti,ab,kw or (Diazoxide or Hyperstat or Proglycem):ti,ab,kw or (Hydralazine or Apo-Hydralazine or Apresoline or Dralzine):ti,ab,kw or (minoxidil or Loniten):ti,ab,kw or (Isosorbide Dinitrate or Dilatrate or Cedocard or Isoket or Isotrate or Isordil or Sorbitrate):ti,ab,kw
#181 MeSH descriptor Nitroglycerin explode all trees
#182 MeSH descriptor Phosphodiesterase Inhibitors explode all trees
#183 (nitroglycerin* or Natispray or Nitro-Dur or Nitromist or Nitrospan or Nitrostat or Nitro-Time or Transderm Nitro or Tridil or Trinipatch):ti,ab,kw or (Phosphodiesterase Inhibit* or Phosphodiesterase antagonist* or Antiphosphodiesterase* or Anti-phosphodiesterase* or Phosphoric Diester Hydrolase Inhibit* or Phosphoric Diester Hydrolase antagonist*):ti,ab,kw or (sildenafil or Revatio or tadalafil or vardenafil):ti,ab,kw or (Cilostazol or Pletal):ti,ab,kw
#184 MeSH descriptor Alprostadil explode all trees
#185 MeSH descriptor Epoprostenol explode all trees
#186 MeSH descriptor Iloprost explode all trees
#187 MeSH descriptor Papaverine explode all trees
#188 MeSH descriptor Isoxsuprine explode all trees
#189 (Alprostadil):ti,ab,kw or (Epoprostenol or Flolan or iloprost or Ciloprost or Ventavis):ti,ab,kw or (Endothelin antagonist* or (Endothelin NEAR/1 inhibit*)):ti,ab,kw or (treprostinil or Remodulin or bosentan or Tracleer or ambrisentan or Letairis):ti,ab,kw or (papaverine or isoxsuprine or Duvadilan):ti,ab,kw
#190 MeSH descriptor Adrenergic alpha-Antagonists explode all trees
#191 MeSH descriptor Doxazosin explode all trees
#192 MeSH descriptor Prazosin explode all trees
#193 ((alpha-Adrenergic NEAR/2 block*) or (adrenergic alpha NEAR/2 block*) or (alpha-adrenergic NEAR/2 antagonist*) or (adrenergic alpha NEAR/2 antagonist*) or (alpha block* NEAR/2 adrenergic) or (alpha antagonist* NEAR/2 adrenergic)):ti,ab,kw or (doxazosin or Cardura or Carduran or Diblocin or Doxazomerck or Doxazosin or Progandol):ti,ab,kw or (prazosin or Minipress or Furazosin or Pratsiol):ti,ab,kw or (terazosin or Adecur or Apo-Terazosin or Deflox or Dysalfa or Flotrin or Heitrin or Hytrin or Hytrine or Magnurol):ti,ab,kw
#194 MeSH descriptor Anti-Arrhythmia Agents explode all trees
#195 (Anti-Arrhythmia or Anti-Arrhythmic* or Antiarrhythmia or Antiarrhythmic* or Anti-fibrillatory or Antifibrillatory):ti,ab,kw and (drug or drugs or agent or agents):ti,ab,kw
#196 MeSH descriptor Disopyramide explode all trees
#197 MeSH descriptor Procainamide explode all trees
#198 MeSH descriptor Quinidine explode all trees
#199 MeSH descriptor Mexiletine explode all trees
#200 MeSH descriptor Encainide explode all trees
#201 (disopyramide or Norpace or Rhythmodan):ti,ab,kw or (procainamide or Apo-Procainamide or Biocoryl or Novocainamide or Novocamid or Procamide or Pronestyl or Procan or Procanbid):ti,ab,kw or (quinidine or Apo-Quinidine or Chinidin or Quinidex or Quinora):ti,ab,kw or (Mexiletine):ti,ab,kw or (encainide or Enkaid):ti,ab,kw
#202 MeSH descriptor Flecainide explode all trees
#203 MeSH descriptor Propafenone explode all trees
#204 MeSH descriptor Amiodarone explode all trees
#205 (Flecainide or Tambocor):ti,ab,kw or (propafenone or Apo-Propafenone or Arythmol or Baxarytmon or Fenoprain or Rythmol or Rytmonorm):ti,ab,kw or (amiodarone or Amiodarona or Cordarone or Cordarex or Pacerone or Trangorex):ti,ab,kw or (dofetilide or Tikosyn):ti,ab,kw or (dronedarone or Multaq):ti,ab,kw
#206 MeSH descriptor Cardiotonic Agents explode all trees
#207 MeSH descriptor Digoxin explode all trees
#208 (Cardiotonic or Cardioprotective or Cardio-tonic or Cardio-protective):ti,ab,kw and (drug or drugs or agent or agents or medication* or prescription*):ti,ab,kw
#209 (cardiotonics or cardio-tonics or cardiac stimulant* or myocardial stimulant* or inotropic agent*):ti,ab,kw or (digoxin or Digacin or Digitek or Dilanacin or Lanacordin or Lanicor or Lanoxicaps or Lanoxin or Lenoxin):ti,ab,kw
#210 MeSH descriptor Antilipemic Agents explode all trees
#211 (antilipemic* or anti-lipemic* or hypolipidemic* or hypo-lipidemic*):ti,ab,kw or (antihyperlipemics or anti-hyperlipemics or antihyperlipidemics or anti-hyperlipidemics):ti,ab,kw
#212 (Antilipemic or anti-lipemic or antihyperlipemic or anti-hyperlipemic or antihyperlipidemic or anti-hyperlipidemic or hypolipidemic or hypo-lipidemic):ti,ab,kw and (drug or drugs or agent or agents or medication* or prescription*):ti,ab,kw
#213 MeSH descriptor Cholestyramine Resin explode all trees
#214 MeSH descriptor Colestipol explode all trees
#215 (cholestyramin* or colestyramin* or Cuemid or Quantalan or Questran):ti,ab,kw or (colestipol or Colestid):ti,ab,kw or (colesevelam or CholestaGel or Welchol):ti,ab,kw or (Bile acid sequestrant* or bile acid-binding drug* or bile acid-binding agengt*):ti,ab,kw or (anticholesteremic* or hypocholesteremic* or (cholesterol NEAR/2 inhibitor*) or cholesterol-lowering drug* or cholesterol-lowering agent* or cholesterol-lowering medication*):ti,ab,kw
#216 MeSH descriptor Gemfibrozil explode all trees
#217 MeSH descriptor Lovastatin explode all trees
#218 MeSH descriptor Pravastatin explode all trees
#219 (ezetimibe or Zetia or fenofibrate or Antara or Fenoglide or Fibricor or Lipofen or Lofibra or TriCor or Triglide or Trilipix):ti,ab,kw or (Gemfibrozil or Apo-Gemfibrozil or Lopid or Trialmin):ti,ab,kw or (Hydroxymethylglutaryl-CoA Reductase inhibit*) or (HMG-CoA Reductase inhibit*) or (Hydroxymethylglutaryl-CoA inhibit*) or (Hydroxymethylglutaryl-Coenzyme A inhibit*):ti,ab,kw or (atorvastatin or Liptor or fluvastatin or Lescol or lovastatin or Altocor or Altoprev or Mevacor):ti,ab,kw or (pravastatin or Apo-Pravastatin or Lipostat or Pravasin* or Pravachol or Selektine or rosuvastatin or Crestor):ti,ab,kw
#220 MeSH descriptor Simvastatin explode all trees
#221 MeSH descriptor Niacin explode all trees
#222 MeSH descriptor Anticoagulants explode all trees
#223 MeSH descriptor Warfarin explode all trees
#224 MeSH descriptor Dalteparin explode all trees
#225 (simvastatin or Synvinolin or Zocor):ti,ab,kw or (niacin or Niacor or Niaspan or Nicobid or Nicolar or Nicotinex or Slo-Niacin):ti,ab,kw or (Anticoagulant* or bloodthinn* or blood-thinn*):ti,ab,kw or (warfarin or Apo-Warfarin or Coumadin*):ti,ab,kw or (dalteparin or Fragmin*):ti,ab,kw
#226 MeSH descriptor Heparin explode all trees
#227 MeSH descriptor Platelet Aggregation Inhibitors explode all trees
#228 MeSH descriptor Aspirin explode all trees
#229 MeSH descriptor Ticlopidine explode all trees
#230 (heparin or tinzaparin or Innohep):ti,ab,kw or (platelet* NEAR/2 inhibit*) or antiplatelet* or anti-platelet* or platelet antagonist*or platelet antiaggregant*:ti,ab,kw or (Aspirin or Acetylsalicylic or Acylpyrin or Aloxiprimum or Aspergum or Bufferin or Colfarit or Dispril or Ecotrin or Easprin or Endosprin or Magnecyl or Micristin or Polopirin or Polopiryna or Solprin or Solupsan or Zorprin):ti,ab,kw or (ticlopidine or Ticlid):ti,ab,kw or (clopidogrel or Plavix):ti,ab,kw
#231 MeSH descriptor Diuretics explode all trees
#232 MeSH descriptor Bumetanide explode all trees
#233 MeSH descriptor Ethacrynic Acid explode all trees
#234 MeSH descriptor Furosemide explode all trees
#235 MeSH descriptor Amiloride explode all trees
#236 (diuretic* or water pill*):ti,ab,kw or (Bumetanide or bumex):ti,ab,kw or (ethacrynic acid or Edecrin):ti,ab,kw or (furosemide or Errolon or Fursemide or Fusid or Lasix or torsemide or Demadex or torasemide or k-sparing or potassium-sparing):ti,ab,kw or (Amiloride or Amidal or Amiduret or Kaluril or Midamor or Midoride or Modamide):ti,ab,kw
#237 MeSH descriptor Triamterene explode all trees
#238 MeSH descriptor Bendroflumethiazide explode all trees
#239 MeSH descriptor Chlorothiazide explode all trees
#240 MeSH descriptor Hydrochlorothiazide explode all trees
#241 MeSH descriptor Methyclothiazide explode all trees
#242 (triamterene or Dyrenium or thiazide diuretic*):ti,ab,kw or (Bendroflumethiazide or Bendrofluazide):ti,ab,kw or (chlorothiazide or Chlotride or Diuril):ti,ab,kw or (hydrochlorothiazide or Apo-Hydro or Dichlotride or Esidrex or HydroDIURIL or Microzide or Oretic):ti,ab,kw or (methyclothiazide or Aquatensen or Enduron):ti,ab,kw
#243 MeSH descriptor Polythiazide explode all trees
#244 MeSH descriptor Chlorthalidone explode all trees
#245 MeSH descriptor Indapamide explode all trees
#246 MeSH descriptor Metolazone explode all trees
#247 (polythiazide or Renese):ti,ab,kw or (chlorthalidone or Apo-Chlorthalidone or Hygroton or Thalitone):ti,ab,kw or (indapamide or Lozol or Metindamide):ti,ab,kw or (metolazone or Mykrox or Zaroxolyn or Zytanix):ti,ab,kw
#248 (#130 OR #131 OR #132 OR #133 OR #134 OR #135 OR #136 OR #137 OR #138 OR #139 OR #140 OR #141 OR #142 OR #143 OR #144 OR #145 OR #146 OR #147 OR #148 OR #149 OR #150 OR #151 OR #151 OR #152 OR #153 OR #154 OR #155 OR #156 OR #157 OR #158 OR #159 OR #160 OR #161 OR #162 OR #163 OR #164 OR #165 OR #166 OR #167 OR #168 OR #169 OR #170 OR #171 OR #172 OR #173 OR #174 OR #175 OR #176 OR #177 OR #176 OR #177 OR #178 OR #179 OR #180)
#249 (#181 OR #182 OR #183 OR #184 OR #185 OR #186 OR #187 OR #188 OR #189 OR #190 OR #191 OR #192 OR #193 OR #194 OR #195 OR #196 OR #197 OR #198 OR #199 OR #200 OR #201 OR #202 OR #203 OR #204 OR #205 OR #206 OR #207 OR #208 OR #209 OR #210 OR #211 OR #212 OR #213 OR #214 OR #215 OR #216 OR #217 OR #218 OR #219 OR #220 OR #221 OR #222 OR #223 OR #224 OR #225 OR #226 OR #227 OR #228 OR #229 OR #230)
#250 (#231 OR #232 OR #233 OR #234 OR #235 OR #236 OR #237 OR #238 OR #239 OR #240 OR #241 OR #242 OR #243 OR #244 OR #245 OR #246 OR #247)
#251 (#248 OR #249 OR #250)
#252 (#106 OR #129)
#253 (#251 AND #252)
#254 (#1 OR #3)
#255 Any MeSH descriptor with qualifiers: AD,CT,DE,ME,PK,TO
#256 MeSH descriptor Drug Synergism explode all trees
#257 (interact* or react* or contraindicat* or enhance* or metabolis* or metaboliz* or pharmacokinetic* or synergis* or toxic or toxicit*):ti,ab,kw
#258 (#254 OR #255 OR #256 OR #257)
#259 (#253 AND #258)
#260 (#5 OR #259)
#261 (#5 AND #251)
#262 (#259), from 2005 to 2010
#263 (#259), from 2000 to 2004
#264 (#259), from 1990 to 1999
#265 (#259), from 1950 to 1989
#266 (#5 AND NOT #261

## Herb-Drug Interactions

### MEDLINE (1950 to October 26, 2010)

1. exp Herb-Drug Interactions/
2. ((herb or herbs or herbal or plant or plants or botanic*) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
3. exp Food-Drug Interactions/
4. ((food or foods) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
5. or/1–4
6. limit 5 to human
7. limit 5 to (“in data review” or “in process” or “pubmednotmedline”)
8. 6 or 7
9. limit 8 to “reviews (specificity)”
10. meta analysis.pt.
11. exp meta-analysis as topic/
12. (meta-analy* or metanaly* or metaanaly* or met analy* or integrative research or integrative review* or integrative overview* or research integration or research overview* or collaborative review*).ti,ab.
13. (systematic review* or systematic overview* or technology assessment* or HTA or HTAs).ti,ab.
14. exp Technology assessment, biomedical/
15. health technology assessment winchester england.jn.
16. “cochrane database of systematic reviews”.jn.
17. (evidence report technology assessment or evidence report technology assessment summary).jn.
18. or/10–17
19. 8 and 18
20. 9 or 19

### EMBASE (1980 to October 26, 2010)

1. exp herb drug interaction/
2. ((herb or herbs or herbal or plant or plants or botanic*) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
3. exp food drug interaction/
4. ((food or foods) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
5. or/1–4
6. limit 5 to human
7. limit 6 to “reviews (2 or more terms high specificity)”
8. exp meta analysis/
9. (meta-analy* or metanaly* or metaanaly* or met analy* or integrative research or integrative review* or integrative overview* or research integration or research overview* or collaborative review*).ti,ab.
10. (systematic review* or systematic overview* or technology assessment* or HTA or HTAs).ti,ab.
11. exp biomedical technology assessment/
12. health technology assessment winchester england.jn.
13. “cochrane database of systematic reviews”.jn.
14. evidence report technology assessment.jn.
15. (evidence report technology assessment or evidence report technology assessment summary).jn.
16. or/8–15
17. 6 and 16
18. 7 or 17

### AMED (1985 to October 26, 2010)

1. exp Herb drug interactions/
2. ((herb or herbs or herbal or plant or plants or botanic*) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
3. ((food or foods) and (drug or drugs or medication$1 or prescription$1 or pharmacotherap* or pharmaco-therap*) and (interact* or react* or contraindicat* or metabolis* or metaboliz* or pharmacokinetic* or pharmaco-kinetic*)).ti,ab.
4. or/1–3
5. meta analysis/
6. meta analysis.pt.
7. (meta-analy* or metanaly* or metaanaly* or met analy* or integrative research or integrative review* or integrative overview* or research integration or research overview* or collaborative review*).ti,ab.
8. (systematic review* or systematic overview* or technology assessment* or HTA or HTAs).ti,ab.
9. health technol assess rep.ja.
10. evid rep technol assess summ.ja.
11. cochrane database syst rev.ja.
12. or/5–11
13. 4 and 12

### International Bibliographic Information on Dietary Supplements (IBIDS)

(interact* react* contraindicat* enhanc* pharmacokinetic* synergis* toxic*) +(cardiovascular* “heart disease” “heart diseases”) +(drug drugs agent* medication* prescription* prescribe*)