# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: James Galipeau, Mary Gauthier, and Mistrel Pratt assisted with project management, screening, data extraction, and development of the evidence tables; Katja Boehm and Stefania Milazzo assisted with screening of the German articles; Ranjeeta Mallick and Lucy Turner provided statistical support and consultations for data analysis.