# Technical Expert Panel

Timothy G. Beukelman, M.D.

University of Alabama at Birmingham

Birmingham, AL

Dennis Dietzen, Ph.D.

Washington University School of Medicine

St. Louis, MO

James N. Jarvis, M.D.

Oklahoma University Health Sciences Center

Oklahoma City, OK

Charles H. Spencer, M.D.

Ohio State University

Columbus, OH