# Summary and Discussion

## Summary

### Incidence and Prevalence of Musculoskeletal Pain in Children and Adolescents

Studies that have investigated the prevalence of musculoskeletal (MSK) pain in children report a wide range of prevalence from 2 to 52 percent. Noninflammatory causes of MSK pain account for the majority of diagnoses (97 percent). No studies reported the prevalence of joint swelling in children.

### Prevalence of Test Positivity in Healthy Children and Adolescents

From the studies included in our review, among the healthy control groups, the median antinuclear antibody (ANA) positivity is three percent, median RF positivity is zero percent, and CCP positivity is less than one percent.

### Test Performance of ANA, RF, and CCP in Children and Adolescents With Undiagnosed MSK Pain

Only one retrospective cohort study examined the test performance of rheumatoid factor (RF) to diagnose juvenile idiopathic arthritis (JIA) among children with MSK pain. It demonstrated a sensitivity (Sn) of 5 percent and a specificity (Sp) of 98 percent. Fifteen case-control studies did not specifically address the test performance of RF among children with MSK pain. The strength of evidence is low for both Sn and Sp (Table 8). Further evidence is likely to change our confidence in the estimates of performance, and is likely to change the estimates.

Table 8 Summary of evidence of the diagnostic characteristics of ANA, RF, and CCP tests for pSLE and JIA in children with undiagnosed MSK pain

Key Questions | N Studies, Sample Size | Sensitivity Range (median)^*^ | Specificity Range (median) | PPV Range (median) | NPV Range (median) | Strength of Evidence
KQ 3: Test performance
3.1 ANA – pSLE | 2 case-control, 201 | 91–100% | 84–85% | 71–84% | 96–100% | Insufficient
3.2 ANA – JIA | 8 case-control, 1,382 | 1–62% (54) | 73–100% (95) | 88–100% (96) | 15–70% (30) | Insufficient
3.3 RF (IgM) – pSLE | 1 case-control, 46 | 29% | 88% | 50% | 74% | Insufficient
3.4 RF (IgM) – JIA | 1 cohort study, 437 | 5% | 98% | 45% | 77% | Low
3.4 RF (IgM) – JIA | 15 case-control, 1,647 | 0–35% (11) | 94–100% (100) | 0–100% (100) | 20–71% (48) | Insufficient
3.5 CCP – pSLE | No studies | | | | | Insufficient
3.6 CCP – JIA | 7 case-control, 1,643 | 2–42% (6) | 93–100% (100) | 20–100% (100) | 11–71% (28) | Insufficient
KQ 4: Accuracy modifiers | No studies | NA | NA | NA | NA | Insufficient
KQ 5: Clinical impacts | No studies | NA | NA | NA | NA | Insufficient

* Median not presented if ≤ 4 studies.

ANA = antinuclear antibody; CCP = cyclic-citrullinated peptide; IgM = immunoglobulin M; JIA = juvenile idiopathic arthritis; KQ = Key Question; NA = not applicable; NPV = negative predictive value; PPV = positive predictive value; N = number; pSLE = pediatric systemic lupus erythematosus; RF = rheumatoid factor

The 12 case-control studies looking at other test-disease combinations did not specifically address the prevalence of positive tests for ANA or cyclic-citrullinated peptide (CCP) among children presenting with MSK pain. The strength of evidence is insufficient to determine the test performance of ANA or CCP to diagnose JIA or pediatric systemic lupus erythematosus (pSLE) in children with undiagnosed MSK pain (Table 9).

A general pattern of high Sp and low Sn was observed for almost all the test-disease combinations; however, the design of case-control studies may lead to bias.52–54 The selective inclusion of cases with established disease (i.e., JIA or pSLE) is likely to lead to an overestimation of Sn. The inclusion of healthy controls is expected to decrease the likelihood of false positive test results and lead to an overestimation of Sp.

## Implications

There is insufficient evidence to determine the test performance of ANA or CCP in children with undiagnosed MSK pain. The strength of evidence is low for the utility of RF in the diagnosis of JIA in children with undiagnosed MSK pain. A result of high Sp and low Sn was observed for almost all the test-disease combinations. The generally low Sn suggests that it is inappropriate to use these tests in isolation (i.e., without clinical assessment) to make a diagnosis of JIA and pSLE. In spite of the high Sp, the low prevalence of JIA and pSLE in the target population (i.e., children with undiagnosed MSK pain) makes the tests of limited diagnostic value. The presence of other clinical characteristics (e.g., morning stiffness, joint swelling, malar rash, cytopenia) may increase the pretest probability of the disease in question. While both the Sn and Sp for ANA for pSLE were high, this test in isolation has limited diagnostic value for children with undiagnosed MSK given the very low prevalence of pSLE, and up to 18 percent prevalence of false positive ANA in the general population.

## Limitations

The generally insufficient strength of evidence is primarily attributable to the high risk of spectrum bias in the case-control studies, a result of the distinct disease and control groups not being representative of the target population of children with undiagnosed MSK pain. For studies examining ANA for pSLE, incorporation bias is a concern because ANA is considered one of the classification criteria for SLE.55

There is no evidence with which to assess the impact of potential accuracy modifiers, and there is no evidence with which to assess the clinical utility of the tests including the impact of the test results on referrals, ordering of additional tests, patient management, and patient and parent anxiety levels.

In addition to the issues identified above, there are general limitations for systematic reviews such as publication bias. We addressed this issue by conducting a comprehensive search of the published literature for potentially relevant studies. Search strategies included combinations of subject headings and free text words. Even though we applied a diagnostic search filter to the search strategies of the electronic databases, our searches identified over 11,000 records. Furthermore, these searches were supplemented by hand searching for grey literature (i.e., unpublished or difficult to find studies). There is also a possibility of study selection bias. However, we employed at least two independent reviewers to identify potentially relevant studies, and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons.

## Conclusion

Most of the evidence from the 28 studies included in this review was not applicable to the population of interest as studies examined children with known disease rather than with undiagnosed MSK pain. No studies addressed children with joint swelling. No study provided a complete investigation on accuracy modifiers. No studies examined clinically important outcomes such as the impact of the test results on referrals, ordering of additional tests, patient management, and patient and parent anxiety levels.

Because the Sn and Sp of these tests have yet to be verified, current evidence does not support their use as diagnostic tests for children with undiagnosed MSK pain. They have a potential application as an adjunct to a clinical assessment that suggests the presence of an inflammatory arthritis or connective tissue disease.

## Future Research

The following general recommendations for future research are based on the preceding discussion of the evidence.

- In order to better understand the natural history of MSK pain in children and the probability of a diagnosis of JIA or pSLE in this population, prospective cohort studies of children and adolescents with MSK pain are needed. Given the low prevalence of JIA and pSLE, a sufficiently large number of participants is required.
- For the research to be generalizable, researchers need to use consistent test methodology and cutoffs as well as consistent and well-accepted clinical criteria for the diagnoses of JIA and pSLE.
- Potential accuracy modifiers of test performance need to be examined, including age, sex, race, history of recent infections, presence of clinical characteristics other than MSK pain (e.g., morning stiffness, joint swelling, uveitis, malar rash, cytopenias).
- The clinical impact of these tests (e.g., referral decisions, additional tests ordered, clinical management, quality of life, psychological distress of child and/or parents) should be assessed in cohort studies.
- Efforts are needed to improve the overall quality of reporting of primary studies of diagnostic test accuracy. The STARD checklist includes 25 items that address the level of detail that should be specified within such studies including descriptions of participants, test methods, statistical methods, and results.56 This could be considered as a guide for authors reporting studies that evaluate diagnostic tests.