# Results: Part Two

## Literature Search

The search strategies identified 11,994 citations from electronic databases and hand searching (Figure 2). Initial broad screening identified 496 potentially relevant citations. Of these, we included one retrospective cohort study and 27 case-control studies; all 28 studies addressed KQ 3 (diagnostic performance). No study provided subgroup data to address KQ 4 (diagnostic modifiers). No study addressed KQ 5 (test impacts). See Appendix D for a list of excluded studies.

Figure 2 Results of literature search, retrieval, and selection

Figure 2 is a flow chart that summarizes the results of literature search, retrieval and selection. It begins with the total number of citations retrieved and ends with the total number of included studies according to each key questions. After duplicate removal 11,586 unique studies were identified through electronic searches with 109 additional studies identified through conference proceedings. 11,695 studies were screened with 11,199 studies excluded leaving 496 articles for full-text screening. 30 studies were not screened because 6 were foreign language and 24 were not available through interlibrary loan. 466 full-text studies were assessed and 438 were excluded. Of these studies, 6 were duplicate publications, 129 were incorrect study design, 77 looked at a population not of interest, 64 did not look at an index test, 7 did not include a reference standard and 155 did not include an outcome of interest. 28 studies were included and reported on diagnostic accuracy (KQ 3). No study reported on diagnostic modifiers (KQ 4) or clinical outcomes (KQ 5).

## Characteristics of Included Studies

The 28 included studies were published between 1966 and 2009 (Appendix F). The mean age (where reported) of children ranged from 6.4 to 15 years of age. The studies were all published as full manuscripts in peer-reviewed journals. Thirteen studies24,30,31,33,37–39,41,43,44,46,48,49 were conducted in Europe, nine 26,28,29,32,35,36,45,47,50 in North America, two40,42 in South America, three27,34,51 in Asia, and one25 in Africa. Nine studies26,28,32,37,39,45,46,48,50 received funding from government, four24,30,34,51 from academic institutions, and four27,31,41,47 from noncommercial institutions. The remaining 11 studies25,29,33,35,36,38,40,42–44,49 did not report the source of funding.

One study36 used a retrospective cohort design and included the spectrum of children with diagnosed and undiagnosed MSK pain. The remaining 27 studies used a case-control type design. The ANA test was examined in nine studies (two26,27 for pSLE and eight26,28–34 for JIA). The RF test was examined in 17 studies (one35 for pSLE and 16^28,30,33,35–47^ for JIA). The CCP test was examined in seven studies24,25,30,48–51 for JIA. There were no studies that examined the CCP test for pSLE.

All of the studies included patients with MSK pain; none specifically addressed children with joint swelling.

### Methodological Quality of Included Studies

The methodological quality of the 28 included studies is summarized in Figure 3; summary tables are presented in Appendix E. Overall, there is substantial concern regarding spectrum bias. Most studies (97 percent) were rated “no” regarding the representativeness of the study population due to the case-control study design. The selection criteria of the population were not described adequately in most studies (83 percent). For studies examining ANA for pSLE, incorporation bias is a concern because ANA is considered one of the classification criteria for SLE.55

Figure 3 Methodological quality of studies evaluating ANA, RF, and CCP tests for pSLE and JIA in children with undiagnosed MSK pain

ANA = antinuclear antibody test; CCP = cyclic-citrullinated peptide; JIA = juvenile idiopathic arthritis; MSK = musculoskeletal; pSLE = pediatric systemic lupus erythematosus; RF = rheumatoid factor

Figure 3 is a bar graph which reports the methodological quality of the included studies. The 13 quality domains are displayed along the y-axis of the bar graph. Percentages out of 100, increasing at 10 point increments, are displayed along the x-axis. Shaded horizontal bars divided into 3 parts report how the studies were rated. Dark shading represents a ‘yes’ rating, indicating the study met the criteria; light shading represents ‘unclear’, and medium shading represents ‘no’, the criteria was not met. For spectrum composition 4% of the studies were rated yes and 96% no. For selection criteria, 12% yes, 10% unclear and 78% no. Reference standard, 82% yes, 14% unclear, 4% no. Test result definition, 78% yes, 13% unclear, 9% no. Disease progression bias, 61% unclear and 39% no. Partial verification, 96% yes and 4% unclear. Differential verification, 91% yes and 9% unclear. Incorporation bias, 91% yes, 3% unclear and 6% no. Index test execution, 72% yes, 19% unclear and 9% no. Test review bias, 75% yes, 25% unclear). Reference standard review bias, 91% yes, 9% unclear. Uninterpretable results, 91% yes, 9% unclear. Withdrawals, 88% yes, 3% unclear and 9% no.

## Key Question 3.1 Antinuclear Antibody Test for Pediatric Systemic Lupus Erythematosus

### Study Characteristics

Two case-control studies26,27 including 201 children (67 pSLE, 134 controls) examined the prevalence of a positive ANA test in children with pSLE and control groups including healthy children and children scheduled for elective orthopedic surgery (Table 2). No information was provided in either study about the presence or absence of MSK pain or joint swelling in either the patient or the control groups.

Table 2 Description of studies evaluating an ANA test for pSLE in children with undiagnosed MSK pain

Author Year Location | Design | Funding | Source of Study Population | Control | Classification Criteria | Assay Method | Positive Threshold
Fawcett26 1999 | Case-control | Government | NR | Underwent elective orthopedic surgical procedures | ACR | IIF | Discernible fluorescence pattern at titer 1:40
Wananukul27 2005 | Case-control | Non-commercial institution | NR | Scheduled for elective surgery (adenotonsillectomy, herniorrhaphy or plastic surgery) | ACR | IIF | Titer ≥ 1:40

ANA = antinuclear antibody test; ACR = American College of Rheumatologists; IIF = indirect immunofluorescence method; MSK = musculoskeletal; pSLE = pediatric systemic lupus erythematosus; NR = not reported

The assay method of the index test in both studies was indirect immunofluorescence (IIF). Both studies used a positive cutoff titer of ≥1:40.

### Quantitative Results

The sensitivities (Sn) were 91 and 100 percent, the specificities (Sp) were 84 and 85 percent, the positive predictive values (PPV) were 71 and 84 percent, and negative predictive values (NPV) were 96 and 100 percent (Figure 4). Among control groups, the proportions of children who tested positive on the ANA test were 16 percent (healthy children) and 15 percent among patients scheduled for elective orthopedic surgeries.

Figure 4 Sensitivity and specificity of an ANA test for pSLE in children with undiagnosed MSK pain

ANA = antinuclear antibody test; FN = false negative; FP = false positive; MSK = musculoskeletal; NRG = nonrheumatic diseases; pSLE = pediatric systemic lupus erythematosus; TN = true negative; TP = true positive

Figure 4 depicts the sensitivity and specificity of an antinuclear antibody test for pediatric systemic lupus erythematosus in children with undiagnosed musculoskeletal pain. The figure reports on 2 case-control studies by Fawcett 1999 and Wananukul 2005. Sensitivity ranged from 0.91 (95% CI: 0.79, 0.98) in Wananukul to 1.00 (95% CI: 0.84, 1.00) in Fawcett. Specificity ranged from 0.84 (95% CI: 0.76, 0.91) in Wananukul to 0.85 (95% CI: 0.65, 0.96) in Fawcett. In the graphical representation, sensitivity for the two studies is fairly consistent but not evenly distributed along a vertical path. For specificity, the two studies are consistent along a vertical path.

## Key Question 3.2 Antinuclear Antibody Test for Juvenile Idiopathic Arthritis

### Study Characteristics

Eight case-control studies26,28–34 including 1,382 children (1,067 JIA, 315 controls) examined the prevalence of a positive ANA test in children with JIA and control groups (Table 3). In four studies all participants were under 18 years of age; two studies28,34 included a small number of young adults. Two studies26,31 did not report age.

Table 3 Description of studies evaluating an ANA test for JIA in children with undiagnosed MSK pain

Author Year Location | Design | Funding | Source of Study Population | Control | Classification Criteria | Assay Method | Positive Threshold
Fawcett26 1999 U.S. | Case-control | Government | NR | NRG: Undergoing elective orthopedic surgical procedures | ACR | IIF | Positive if a clearly discernible fluorescence pattern appears at 1:40 serum dilation
Haynes28 1986 U.S. | Case-control | Government and non-commercial institution | NR | NRG: Age-matched children with nonrheumatic diseases | ACR | IIF | Reading of ≥1+ in fluorescence at 1:20 dilution
Jones29 2006 North America | Case-control | NR | Randomly selected patients from multiple medical centers | NRG: Patients with acute lymphoblastic leukemia | NR | NR | Titer > 1:80
Lipinska30 2008 Poland | Case-control | Academic institution | NR | NRG: Children with functional CV system dysfunction | ILAR | IIF | Titer > 1:320
Nordal31 2009 Norway | Case-control | Non-commercial institution | NR | NRG: Children undergoing elective outpatient procedures; no diagnosis of inflammatory diseases | ILAR | IIF | Titer > 1:80
Osborn32 1984 U.S. | Case-control | Government | Pediatric clinic | Healthy and ORG | ACR | IIF | Titer > 1:40
Siamopoulou-Mavridou33 1991 Greece | Case-control | NR | NR | Healthy | EULAR | IIF | Titer > 1:40
Wakhlu34 2003 India | Case-control | Academic institution | Immunology clinic | Healthy | ACR | IIF | Titer: > 1:40

ANA = antinuclear antibody test; ACR = American College of Rheumatology; CV = cardiovascular; EULAR = The European League Against Rheumatism; IIF = indirect immunofluorescence method; ILAR = International League of Associations for Rheumatology; JIA = juvenile idiopathic arthritis; MSK = musculoskeletal; NR = not reported; NRG = nonrheumatic disease group; ORG = other rheumatic diseases group

For the control groups, three studies32–34 included healthy children, five26,28–31 included children with nonrheumatic conditions, and one32 included children with other rheumatic diseases. Three studies29,31,34 recruited JIA patients from general hospitals or clinics, and the source was unreported by the remaining studies. For the classification of JIA, four studies26,28,32,34 used the ACR criteria, two30,31 used the ILAR criteria, one33 used the EULAR criteria, and the classification criteria were unreported in one study.29 Only one study (Nordal, et al.,31) looked at children with MSK pain who either had a diagnosis of JIA or acute lymphoblastic leukemia; none of the other studies commented on the presence or absence of MSK pain or joint swelling in either the patient or control groups. The frequency of uveitis or iridocyclitis was reported by three studies: 18 percent of JIA patients in Nordal, et al.,31 6 percent of JIA patients in Osborn, et al.,32 and 3 percent in Wakhlu, et al.34

IIF was used in all studies except Jones, et al.,29 who did not report the method used. In studies that reported the positive cutoff titers, the titers ranged from >1:20 to >1:320. Fawcett26 and Nordal, et al.,31 examined multiple assay methods of ANA for JIA (Appendix F).

### Quantitative Results

The Sn ranged from 1 to 62 percent (median = 54 percent); the Sp ranged from 73 to 100 percent (median = 95 percent); PPV ranged from 88 to 100 percent (median = 96 percent); and NPV ranged from 15 to 70 percent (median = 30 percent) (Figure 5). Analyses by subtypes of JIA are presented in Appendix G.

Figure 5 Sensitivity and specificity of an ANA test for JIA in children with undiagnosed MSK pain

ANA = antinuclear antibody test; FN = false negative; FP = false positive; JIA = juvenile idiopathic arthritis; MSK = musculoskeletal; NRG = nonrheumatic disease group; TN = true negative; TP = true positive

Figure 5 depicts the sensitivity and specificity of an antinuclear antibody test for juvenile idiopathic arthritis in children with undiagnosed musculoskeletal pain. The figure reports on 8 case-control studies: Fawcett 1999, Haynes 1986, Jones 2006, Lipinska 2008, Nordal 2009, Osborn 1984, S-Mavridou 1991 and Wakhlu 2003. Sensitivities ranged from 0.01 (95% CI: 0.00, 0.05) in Wakhlu to 0.62 (95% CI: 0.54, 0.69) in Fawcett. Specificities ranged from 0.73 (95% CI: 0.60, 0.83) in Osborn to 1.00 (95% CI: 0.86, 1.00) in Wakhlu. On the graphic, sensitivity for the 8 studies is scattered with no pattern to the points; for specificity, the results are scattered but fairly consistent along a vertical path.

Among the healthy controls, the proportion of children (three groups32–34) who tested positive for ANA ranged from 0 to 27 percent (median = 3). Among controls with nonrheumatic conditions,26,28–31 the proportion of children with positive tests ranged from 0 to 18 percent (median = 6). There were two studies that reported very low Sn. Both had zero percent prevalence of a positive ANA among controls. In one,30 this could be explained by their use of a high cutoff titer of >1:320. In the other study34 the reason for the disparity is unclear.

## Key Question 3.3 Rheumatoid Factor Test for Pediatric Systemic Lupus Erythematosus

### Study Characteristics

One case-control study by Hanson, et al.,35 examined the prevalence of a positive IgM-RF test in 14 children with pSLE and 32 controls. The study was published in 1966. The assay method for the RF test was latex fixation. As the study was conducted prior to the development of the ACR criteria for the classification of SLE, patients were diagnosed based on criteria developed by Cook, et al.,93 and Urbach.94 The control groups comprised a mix of healthy children and children with other rheumatic conditions and ulcerative colitis. The study did not comment on the presence or absence of MSK pain or joint swelling in either the patients or controls.

### Quantitative Results

The Sn was 29 percent and Sp was 88 percent.35 The proportion of children who tested positive for RF was 13 percent.

## Key Question 3.4 Rheumatoid Factor Test for Juvenile Idiopathic Arthritis

### Study Characteristics

One retrospective cohort study by Eichenfield, et al.,36 examined the records of pediatric patients who had a RF test and were seen in the walk in clinic, inpatient service, emergency department, or Pediatric Rheumatology Center at The Children's Hospital of Philadelphia (Table 4). Among the 437 patient records that were evaluated, 105 had a diagnosis of JIA according to ACR criteria. The remaining 332 patients (combined into one control group) had a mix of MSK complaints (n = 201) or symptoms suggestive of an underlying autoimmune disease (n = 131).

Table 4 Description of studies evaluating an RF (IgM) test for JIA in children with undiagnosed MSK pain

Author Year Location | Funding | Source of Study Population | Non-disease Group | Classification Criteria | Assay Method | Positive Threshold
Cohort Study
Eichenfield36 1986 U.S. | NR | Consecutive patients from pediatric hospital | NA (due to cohort design) | ACR | Latex fixation test | Titer > 1:80
Case-Control Studies
Andersson-Gare37 1994 Sweden | Government | Epidemiological survey in south-western Sweden | Healthy | EULAR | EIA | Mean of control group + 2 sd
Balogh38 1980 Hungary | NR | Hospital consecutive patients | Healthy: Age- and sex-matched | EULAR/WHO workshop | Latex fixation test | NR
Egeskjold39 1981 Denmark | Government | NR | Healthy: Age- and sex-matched | ACR | IIF | Titer > 1:9
Egeskjold46 1982 Denmark | Government | NR | Healthy | ACR | IIF | Maximum of peak 2 displacement beyond normal range
Ferreira40 2007 Brazil | NR | Randomly selected patients from multiple centers of pediatric rheumatology | Healthy | ACR | Latex fixation test | Latex: 20 IU/ml
Hanson35 1966 U.S. | NR | NR | Healthy, NRG, ORG | Unclear | Latex fixation test | Titer > 1:160
Haynes28 1986 U.S. | Government and non-commercial institution | NR | NRG: Age-matched children with nonrheumatic diseases | ACR | EIA | Mean of control + 2 sd
Lipinska30 2008 Poland | Academic institution | NR | NRG: Age- and sex-matched children with functional cardiovascular system dysfunction | ILAR | EIA | 24 RU/ml
Permin41 1982 Denmark | Non-commercial institution | NR | Healthy | ACR | IIF | Titer > 1:10
Roizenblatt42 1983 Brazil | NR | Pediatric clinic | ORG: Age- and sex- matched hypermobile children | ACR | EIA | Mean of control group + 2 sd
Saulsbury47 1990 U.S. | Non-commercial institution | NR | Healthy | ACR | EIA | Titer > 1:20
Siamopoulou-Mavridou33 1991 Greece | NR | NR | Healthy: Age- and sex-matched children without rheumatic disease | EULAR | Latex fixation test | Mean optical density of healthy control + 3 sd
Taseski43 1981 Yugoslavia | NR | NR | Healthy and ORG (collagen diseases) | NR | Latex slide test | Agglutination visually detectable
Varbanova44 1999 Bulgaria | NR | NR | Healthy | EULAR | EIA | Mean IU of healthy control + 2 sd
Wernick45 1981 U.S. | Government | NR | NRG (scoliosis and neurologic diseases) | ACR | Solid phase radioimmunoassay | Mean of normal control + 2 sd

ACR = American College of Rheumatology; EULAR = The European League Against Rheumatism; EIA = enzyme immunoassay; IgM = immunoglobulin M; IIF = indirect immunofluorescence; ILAR = International League of Associations for Rheumatology; IU = international unit; JIA = juvenile idiopathic arthritis; ml = milliliter; MSK = musculoskeletal; NA = not applicable; NR = not reported; NRG = nonrheumatic disease group; ORG = other rheumatic diseases group; RF = rheumatoid factor; RU = relative unit; sd= standard deviation; WHO = World Health Organization

Fifteen case-control studies examined the prevalence of a positive RF in children with JIA and controls (Table 4). The diagnosis was based on the ACR criteria in nine studies,28,36,39–42,45–47 the EULAR criteria in four,33,37,38,44 and the ILAR criteria in one.33 Two35,43 did not state which classification criteria were used. In one study, 62 percent of patients had chronic bilateral iridocyclitis.46 For the control groups, nine studies33,37–41,44,46,47 used healthy children, three28,30,45 used children with nonrheumatic conditions, one42 used children with other rheumatic conditions, and two studies35,43 used a mixed group that included healthy children and children with nonrheumatic and other rheumatic conditions. None of the case-control studies commented on the presence or absence of MSK pain or joint swelling in the patient or control groups. Studies reporting data on non-IgM RF tests are presented in Appendix F.

### Quantitative Results

Results from the cohort study by Eichenfield, et al.,36 show an Sn of 5 percent and a Sp of 98 percent (Figure 6). This is consistent with the RF results from the same center’s total JIA population (6.9 percent) as reported in their paper. The authors also analyzed the post-test probability of JIA based on the reported Sn and Sp. The analyses take into account the pretest probability or prevalence of JIA, which in this cohort was 24 percent. The results showed that probability of JIA increased to 45 percent with a positive test. They also showed that in a “typical” primary care practice, the probability of JIA went from 0.3 percent to 0.7 percent with a positive test.

Figure 6 Sensitivity and specificity of an RF (IgM) test for JIA in children with undiagnosed MSK pain

FN = false negative; FP = false positive; IgM = immunoglobulin M; JIA = juvenile idiopathic arthritis; MSK = musculoskeletal; NRG = nonrheumatic disease group; ORG = other rheumatic diseases group; RF = rheumatoid factor; TN = true negative; TP = true positive.

Figure 6 depicts the sensitivity and specificity of the rheumatoid factor test for juvenile idiopathic arthritis in children with undiagnosed musculoskeletal pain. It comprises 2 parts. Part 1 shows the results for one cohort study by Eichenfield 1986, had a sensitivity of 0.05 (95% CI: 0.02, 0.11) and a specificity of 0.98 (95% CI: 0.96, 0.99). Part 2 reports on 15 case-control studies: Andersson-Gare 1994, Balogh 1980, Egeskjold 1981, Egeskjold 1982, Ferreria 2007, Hanson 1996, Haynes 1986, Lipinska 2008, Permin 1982, Rojzenblatt 1983, S-Mavridou 1991, Saulsbury 1990, Taseski 1981, Varbanova 1999, and Wernick 1981. Sensitivity ranged from 0.00 (95% CI: 0.00, 0.09) in Taseski to 0.35 (95% CI: 0.24, 0.48) in Hayes, and specificity ranged from 0.94 (95% CI: 0.79, 0.99) in Wernick to 1.00 (95% CI: 0.94, 1.00) in Varbanova.

Fifteen case-control studies, including 1,647 children (986 JIA, 661 controls) examined the prevalence of a positive IgM-RF test (Figure 6). Sn ranged from 0 to 35 percent (median = 11 percent), Sp ranged from 94 to 100 percent (median = 100 percent), PPV ranged from 0 to 100 percent (median = 100 percent), and NPV ranged from 20 to 71 percent (median = 48 percent).

The proportion of healthy children who tested positive ranged from 0 to 3 percent (median = 0). For the controls with nonrheumatic conditions, the proportion ranged from 0 to 6 percent (median = 5). For the controls (two groups) that included a mix of healthy children and children with other conditions, the proportion that tested positive ranged from 2 to 5 percent. There does not appear to be a relationship between the cutoff titer used (if reported) and Sn. Analyses by subtypes of JIA are presented in Appendix G.

## Key Question 3.5 Cyclic-Citrullinated Peptide Test for Pediatric Systemic Lupus Erythematosus

No studies provided information to address this question.

## Key Question 3.6 Cyclic-Citrullinated Peptide Test for Juvenile Idiopathic Arthritis

### Study Characteristics

Seven case-control studies24,25,30,48–51 including 1,643 participants (729 JIA, 914 control) examined the prevalence of a positive CCP test in children with JIA and controls (Table 5). None of the studies reported on the presence or absence of MSK pain or joint swelling in either the patient or control groups.

Table 5 Description of studies evaluating a CCP test for juvenile idiopathic arthritis in children with undiagnosed MSK pain

Author Year Location | Design | Funding | Source of Study Population | Control | Classification Criteria | Assay Method | Positive Threshold
Avcin 2002^48^ Italy and Slovenia | Case-control | Government | NR | Healthy | NR | EIA | 70 units
Brunner 2006^49^ Germany | Case-control | NR | NR | Healthy, other autoimmunopathies, NRG (undergoing cardiac therapy) | NR | EIA | 2.5 RU
Ferucci 2005^50^ U.S. | Case-control | Government | Cohort from Cincinnati and NIAMSD registry | Healthy | ACR | EIA | 5 units/ml
Habib 2008^25^ Egypt | Case-control | NR | NR | Healthy | ILAR | EIA | 20 units/ml
Lipinska 2008^30^ Poland | Case-control | Academic institution | NR | NRG (functional cardiovascular system dysfunction) | ILAR | EIA | 5 RU
Kasapcopur 2004^24^ Turkey | Case-control | Academic institution | Consecutive patients admitted to hospital outpatient department | Healthy | ILAR | EIA | 5 RU
Kwok 2005^51^ Hong Kong | Case-control | Academic institution | NR | NRG (allergy, idiopathic thrombocytopenia, and hepatitis C) | ILAR | EIA | 20 units

ACR = American College of Rheumatology; CCP = cyclic-citrullinated peptide; EIA = enzyme immunoassay; ILAR = International League of Associations for Rheumatology; ml = milliliter; MSK = musculoskeletal; NR = not reported; RU = relative unit

The control group in four studies24,25,48,50 consisted of healthy children; two studies used a nonrheumatic patient control group (cardiovascular dysfunction,30 allergies and idiopathic thrombocytopenia51). One study49 used a mixed group of healthy children and children with other autoimmune diseases as their comparator. Four studies24,25,30,51 used the ILAR criteria for classification of JIA; one study50 used ACR criteria. All seven studies used the EIA method; however, different cutoff points were used. It is not clear from the reported methods which anti-CCP assays were used in the studies.

### Quantitative Results

The Sn ranged from 2 to 42 percent and Sp ranged from 93 to 100 percent (Figure 7). The PPV ranged from 20 to 100 percent and NPV ranged from 11 to 71 percent. The proportion of healthy controls (four groups) that tested positive for CCP ranged from 0 to 0.6 percent (median = 0). The proportion of controls with nonrheumatic conditions (two groups) that tested positive ranged from 0 to 4 percent (median = 2). Among the mixed controls (one group), 7 percent tested positive. Subgroup analyses by subtypes of JIA are presented in Appendix G.

Figure 7 Sensitivity and specificity of a CCP test for JIA in children with undiagnosed MSK pain

CCP = Cyclic-citrullinated peptide; FN = false negative; FP = false positive; JIA = juvenile idiopathic arthritis; MSK = musculoskeletal; NRG = nonrheumatic disease group; TN = true negative; TP = true positive

Figure 7 depicts the sensitivity and specificity of a cyclic-citrullinated peptide test for juvenile idiopathic arthritis in children with undiagnosed musculoskeletal pain. The figure reports on 7 case-control studies: Avcin 2002, Brunner 2006, Ferucci 2005, Habib 2008, Kasapcopur 2004, Kwok 2005, and Lipinska 2008. Sensitivity ranged from 0.02 (95% CI: 0.00, 0.06) in Avcin to 0.42 (95% CI: 0.32, 0.52) in Lipinska, and specificity ranged from 0.93 (95% CI: 0.87, 0.97) in Brunner to 1.00 (95% CI: 0.88, 1.00) in Avcin.

## Key Question 4.1 Accuracy Modifiers of Antinuclear Antibody, Rheumatoid Factor, Cyclic-Citrullinated Peptide Test for Pediatric Systemic Lupus Erythematosus

No studies provided data on accuracy modifiers (age, sex, race or ethnicity, comorbidities, recent infections) for any of the tests for pSLE.

## Key Question 4.2 Accuracy Modifiers of Antinuclear Antibody, Rheumatoid Factor, Cyclic-Citrullinated Peptide Test for Juvenile Idiopathic Arthritis

No studies provided data on accuracy modifiers (age, sex, race or ethnicity, comorbidities, recent infections) for any of the tests for JIA.

## Key Question 5 Clinical Impacts due to the Results of Antinuclear Antibody, Rheumatoid Factor, and Cyclic-Citrullinated Peptide Tests

No studies provided information to address this question.

## Rating the Body of Evidence

The body of evidence was assessed using the AHRQ system for grading the strength of evidence (Table 6). All case-control studies were assessed as “high risk of bias” primarily due to spectrum bias and lack of adequate reporting of selection criteria. Therefore, strength of evidence derived from case-control studies was initially assessed as “low”. This assessment was downgraded to “insufficient” when other limitations were noted in any of the other domains. All studies were considered to provide “indirect” evidence due to the use of surrogate outcomes (i.e., test performance) instead of health outcomes.

Table 6 Strength of evidence for ANA, RF, and CCP tests for pSLE and JIA in children with undiagnosed MSK pain

Key Question | N Studies, (N disease; N control) | Outcome | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
ANA – pSLE | 2 c-c (67; 134) | Sn | High | Consistent | Indirect | Precise | Insufficient
ANA – pSLE | 2 c-c (67; 134) | Sp | High | Consistent | Indirect | Precise | Insufficient
ANA – JIA | 8 c-c (1,067; 315) | Sn | High | Inconsistent | Indirect | Imprecise | Insufficient
ANA – JIA | 8 c-c (1,067; 315) | Sp | High | Consistent | Indirect | Precise | Insufficient
IgM-RF – pSLE | 1 c-c (14; 32) | Sn | High | Unknown (single study) | Indirect | Imprecise | Insufficient
IgM-RF – pSLE | 1 c-c (14; 32) | Sp | High | Unknown (single study) | Indirect | Imprecise | Insufficient
IgM-RF – JIA | 1 cohort (437) | Sn | Medium | Unknown (single study) | Indirect | Imprecise | Low
IgM-RF – JIA | 1 cohort (437) | Sp | Medium | Unknown (single study) | Indirect | Imprecise | Low
IgM-RF – JIA | 15 c-c (986; 661) | Sn | High | Inconsistent | Indirect | Imprecise | Insufficient
IgM-RF – JIA | 15 c-c (986; 661) | Sp | High | Consistent | Indirect | Precise | Insufficient
CCP – pSLE | No studies | NA | NA | NA | NA | NA | Insufficient
CCP – JIA | 7 c-c (729; 914) | Sn | High | Inconsistent | Indirect | Imprecise | Insufficient
CCP – JIA | 7 c-c (729; 914) | Sp | High | Consistent | Indirect | Precise | Insufficient
Accuracy modifiers | No studies | NA | NA | NA | NA | NA | Insufficient
Clinical impact of tests | No studies | NA | NA | NA | NA | NA | Insufficient

ANA = antinuclear antibody; c-c = case-control; CCP = cyclic-citrullinated peptide; IgM = immunoglobulin M; JIA = juvenile idiopathic arthritis; N = number; MSK = musculoskeletal; NA = not applicable; RF = rheumatoid factor; pSLE = pediatric systemic lupus erythematosus; Sn = sensitivity; Sp = specificity

### Applicability

Applicability refers to how generalizable the findings of this report are to a wider range of populations that vary by age, sex, clinical presentation, disease severity, and clinical setting. The study populations were relatively heterogeneous in terms of the ethnicity, and a wide range of conditions were included. The age of the participants was similarly broad, as was the age of disease onset (generally between age 1 and 15 years when it was reported). The settings in which the tests were conducted also varied. Disease activity and severity were rarely described, but when reported more than half of the study participants had active disease. The diagnostic performance of the tests did not appear to differ significantly across the spectrum of patients and institutional sources, which would normally imply that the results are generalizable to a broader population.

Only one36 of the 28 studies examined the performance of these tests in children with undiagnosed MSK pain—the primary population of interest for this review. In the study by Eichenfield, et al.,36 even with a highly selected population of children who had undergone an RF test, only 4.8 percent of children with JIA had a positive RF, and 6 of 332 (1.8 percent) of the remaining children—including 115 with only MSK pain—were RF positive. The authors conducted further analyses which demonstrated that in the primary care setting, the pretest probability of 0.3 percent only increased to 0.7 percent with a positive test.

None of the remaining studies reported on the presence or absence of MSK pain in either the patients or controls, and in all of these studies, the patients had known diagnoses of either JIA or pSLE. For this reason, the applicability of the tests to children with undiagnosed MSK pain is unclear. In the clinical setting of MSK pain, physicians are primarily interested in the degree to which the test results might change the probability that a patient with a positive or negative test may or may not have the disease (the positive predictive value [PPV] and negative predictive value [NPV], respectively). The PPV and NPV of these tests will change dramatically depending on the baseline prevalence (or pretest probability) of disease. Therefore, case-control studies that compare children with disease to a healthy population in a 1:1 ratio (a 50 percent disease prevalence) may overestimate test performance and utility. In contrast, in children with undiagnosed MSK pain seen in a primary care setting where prevalence of JIA or pSLE is less than one percent.12 the same test will identify more false positives than true positives. We developed a series of hypothetical scenarios to demonstrate this (Table 7).

Table 7 Hypothetical scenarios for PPV at different baseline disease prevalence

| PPV | NPV
ANA – pSLE (Sn = 91%, Sp = 84%)
Baseline prevalence 1% | 5% | 100%
Baseline prevalence 50% | 85% | 90%
ANA – JIA (Sn = 36%, Sp = 96%)
Baseline prevalence 1% | 8% | 99%
Baseline prevalence 50% | 90% | 60%
RF – JIA (Sn = 12%, Sp = 98%)
Baseline prevalence 1% | 6% | 99%
Baseline prevalence 50% | 86% | 53%
CCP – JIA (Sn = 9%, Sp = 99%)
Baseline prevalence 1% | 8% | 99%
Baseline prevalence 50% | 90% | 52%

ANA = antinuclear antibody; CCP = cyclic-citrullinated peptide; JIA = juvenile idiopathic arthritis; NPV = negative predictive value; PPV = positive predictive value; pSLE = pediatric systemic lupus erythematosus; RF = rheumatoid factor; Sn = sensitivity; Sp = specificity