# Results: Part One

The aim of Key Questions (KQs) 1 and 2 was to provide background information for the interpretation of the results of KQs 3, 4, and 5. Studies were selected based on the availability of the evidence and their representativeness to the pediatric population of North America.

## Key Question 1.1 Incidence and Prevalence of Undiagnosed Musculoskeletal Complaints in Children

In studies of the epidemiology of musculoskeletal (MSK) pain in children, 60–85 percent of school-aged children reported at least one episode of MSK pain within a 3 month period.6,79 More girls reported pain (65 percent) than boys (55 percent).79 Up to 30 percent of children and adolescents reported having experienced chronic pain (including MSK pain) which lasted for more than 6 months.2,80–83 No studies reported the prevalence of joint swelling in children.

The prevalence of MSK pain ranges from 2 percent in 12-year-olds to 52 percent in 18-year-olds.9–11 The prevalence of MSK pain increases steadily with age throughout childhood and adolescence.12,13 Haraldstad, et al.,79 examined 1,238 Norwegian schoolchildren aged 8 to 18 years and found that the prevalence of back pain increased with age for both sexes.79 A 4-year prospective study reported that the incidence of new-onset low back pain doubled with age from 13 percent in 12-year olds to 24 percent in 15-year-olds.80 While some studies reported that low back, neck, shoulder, leg, and chronic pain were more prevalent in girls than boys,79,80,84 two studies found no such difference,85,86 and one found male predominance.13

## Key Question 1.2: The Positivity of Antinuclear Antibody, Rheumatoid Factor, and Cyclic-Citrullinated Peptide Tests in Healthy Children

Nine studies examined the prevalence of a positive ANA in a total of 1,413 healthy children and found a range of 0 to 18 percent14–22 All of these studies examined children and adolescents 18 years old or less except Baig and Shere,18 which included 1- to 19-year olds and Youngchiyud, et al.,21 which included 12- to 20-year olds. The definition of a positive cutoff of ANA titer ranged from 1:5 to 1:40.

Studies on the positivity of the RF and CCP tests in healthy children were scarce. A commentary87 indicated that most children with a positive RF test did not have JIA,36,88 and most children with JIA did not have a positive RF.89 Kasapcopur, et al.,23 investigated 118 healthy Turkish children, using a cutoff of >25 IU/ml, and found a rate of 3 percent RF positivity.23 The prevalence of CCP positivity in healthy children was 0 and 0.6 percent as reported in two studies.24,25

## Key Question 2.1 Noninflammatory Causes of Pediatric Musculoskeletal Pain

De Inocencio12 conducted a retrospective chart review on 317 children between 3 and 15 years of age in a primary care setting in Madrid.12 Noninflammatory etiologies accounted for the overwhelming majority (96.7 percent) of the MSK pain for children seen in primary care. He found that physical trauma (43.6 percent) was the most common cause of pediatric MSK pain, and bone and muscle contusions were the most common trauma subgroup. Other noninflammatory etiologies included overuse (24.0 percent), osteochondroses (10.3 percent), hypermobility (3.3 percent), non-specific pain (7.6 percent), growing pain (3.5 percent), and viral infection (4.5 percent). Non-specific pain, growing pains, and hypermobility were much more common in preschool children (3 to 5 years) than in both school-aged children (6 to 9 years) and adolescents (10 to 14 years).

## Key Question 2.2 Inflammatory Causes of Pediatric Musculoskeletal Pain

De Inocencio12 reported that inflammatory etiologies accounted for a small fraction (3.3 percent) of primary care visits from children with MSK pain, and included toxic synovitis (2.5 percent) and inflammatory arthritis (0.8 percent). This was consistent with an earlier study by McGhee, et al.,59 who conducted a retrospective chart review of 226 children with MSK pain who were referred for an initial rheumatology consultation. Among a group of 111 patients whose only presenting complaint was MSK pain, one child (1 percent) had a rheumatic disease (ankylosing spondylitis), and none had pSLE or JIA. The majority (81 percent) had mechanical MSK or overuse syndromes as explanations of their pain. In addition, the same study observed that among the 76 children diagnosed with JIA, only 12 (16 percent) included pain as part of their main complaints. Earlier observations by Sherry, et al.,90 stated that 14 percent of patients with a confirmed diagnosis of JIA reported no pain. Although the numbers differ, both studies confirm that the absence of MSK pain does not rule out a diagnosis of JIA.

## Key Question 2.3 The Resolution or Recurrence of Pediatric Musculoskeletal Pain

The recurrence of MSK pain was common in children. Thirty-five percent of 14-year olds who previously complained of low back pain reported recurrent episodes at age 18 and into early adulthood.91 Mikkelsson, et al.,92 examined 1,628 school-aged children with weekly pain at baseline and found that 52 percent reported MSK pain at 1-year followup.