# References and Included Studies

1 Mikkelsson M, Salminenb JJ, Kautiainenc H. Non-specific musculoskeletal pain in preadolescents. Prevalence and 1-year persistence. Pain. 1997;73:29-35. [pmid: 9414054].
2 Palermo TM. Impact of recurrent and Chronic pain on child and family daily functioning: a critical review of the literature. J Dev Behav Pediatr. 2000;21(1):58-69. [pmid: 10706352].
3 Junnila J, Cartwright VW. Chronic musculoskeletal pain in children: Part II. Rheumatic causes. Am Fam Physician. 2006;74(2):293-300. [pmid: 16883927].
4 Malleson PN, Beauchamp RD. Rheumatology: 16. Diagnosing musculoskeletal pain in children. CMAJ. 2001;165(2):183-8. [pmid: 11501459].
5 Junnila J, Cartwright VW. Chronic musculoskeletal pain in children: Part I. Initial Evaluation. Am Fam Physician. 2006;74(1):115-22. [pmid: 16848385].
6 Clinch J, Eccleston C. Chronic musculoskeletal pain in children: assessment and management. Rheumatology (Oxford). 2009;48:466-74. [pmid: 19202161].
7 Whiting J, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. 2004;8(25):1-234.
8 Agency for Healthcare Research and Quality. AHRQ guidance for the evaluation of medical tests [draft]. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
9 Goodman JE, McGrath PJ. The epidemiology of pain in children and adolescents: a review. Pain. 1991;46:247-64. [pmid: 1758709].
10 Abu-Arafeh I, Russell G. Recurrent limb pain in school. Arch Dis Child. 1996;74:336-9. [pmid: 8669936].
11 Kristjansdottir G. Prevalence of pain combinations and overall pain: a study of headache, stomach pain and back pain among school children. Scand J Soc Med. 1997;25:58-63. [pmid: 9106948].
12 de Inocencio J. Epidemiology of musculoskeletal pain in primary care. Arch Dis Child. 2004;89:431-4. [pmid: 15102634].
13 Burton AK, Clarke RD, McClune TD, et al. The natural history of low back pain in adolescents. Spine. 1996;21(20):2323-8. [pmid: 8915066].
14 Wananukul S, Voramethkul W, Kaewopas Y, et al. Prevalence of positive antinuclear antibodies in healthy children. Asian Pac J Allergy Immunol. 2005;23:153-7. [pmid: 16252846].
15 Petty RE, Cassidy JT, Sullivan DB. Clinical correlates of antinuclear antibodies in juvenile rheumatoid arthritis. J Pediatr. 1973;83:386-9. [pmid: 4579718].
16 Goel KM, Shanks RA, Whaley K, et al. Autoantibodies in childhood connective tissue diseases and in normal children. Arch Dis Child. 1975;50:419-23. [pmid: 1096832].
17 Arroyave CM, Mary JG, Kent CR, et al. The frequency of antinuclear antibody (ANA) in children by use of mouse kidney (MK) and human epithelial cells (HEp-2) as substrates. J Allergy Clin Immunol. 1988;82:741-4. [pmid: 3263996].
18 Baig MM, Shere SJ. Prevalence of autoantibodies in Saudi population. J Med. 1989:286-90. [pmid: 2809425].
19 Martini A, Lorini R, Zanaboni D, et al. Frequency of autoantibodies in normal children. Am J Dis Child. 1989;143:493-6. [pmid: 2784621].
20 Cabral DA, Petty RE, Fung M, et al. Persistent antinuclear antibodies in children without identifiable inflammatory rheumatic or autoimmune disease. Pediatrics. 1992;89:441-4. [pmid: 1741219].
21 Youngchaiyud U, Youngchaiyud P, Chandanayingyong D, et al. Incidence of autoantibodies in Thais. J Med Assoc Thai. 1981;64:445-8. [pmid: 7028903].
22 Allen RC, Dewez P, Stuart L, et al. Antinuclear antibodies using HEp-2 cells in normal children and in children with common infections. J Paediatr. 1991;27:39-42.
23 Kasapcopur O, Ozbakir F, Arisoy N, et al. Frequency of antinuclear antibodies and rheumatoid factor in healthy Turkish children. Turk J Pediatr. 1999;41(1):67-71. [pmid: 10770678].
24 Kasapcopur O, Altun S, Aslan M, et al. Diagnostic accuracy of anti-cyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. Ann Rheum Dis. 2004;63(12):1687-9. [pmid: 15547097].
25 Habib HM, Mosaad YM, Youssef HM. Anti-cyclic citrullinated peptide antibodies in patients with juvenile idiopathic arthritis. Immunol Invest. 2008;37(8):849-57. [pmid: 18991100].
26 Fawcett PT, Rose CD, Gibney KM, et al. Use of ELISA to measure antinuclear antibodies in children with juvenile rheumatoid arthritis. J Rheumatol. 1999;26(8):1822-6. [pmid: 10451083].
27 Wananukul S, Voramethkul W, Kaewopas Y, et al. Prevalence of positive antinuclear antibodies in healthy children. Asian Pac J Allergy Immunol. 2005;23(2–3):153-7. [pmid: 16252846].
28 Haynes DC, Gershwin ME, Robbins DL. Autoantibody profiles in juvenile arthritis. J Rheumatol. 1986;13(2):358-63. [pmid: 3487649].
29 Jones O, Spencer C, Bowyer S, et al. A multicenter case-control study on predictive factors distinguishing childhood leukemia from juvenile rheumatoid arthritis. Pediatrics. 2006;117(5):e840-e844. [pmid: 16651289].
30 Lipinska J, Smolewska E, Brozik H, et al. Anti-CCP antibodies in children with Juvenile Idiopathic Arthritis (JIA) - diagnostic and clinical significance. Cent Eur J Immunol. 2008;33(1):19-23.
31 Nordal EB, Songstad NT, Berntson L, et al. Biomarkers of chronic uveitis in juvenile idiopathic arthritis: predictive value of antihistone antibodies and antinuclear antibodies. J Rheumatol. 2009;36(8):1737-43. [pmid: 19567622].
32 Osborn TG, Patel NJ, Moore TI, et al. Use of the HEp-2 cell substrate in the detection of antinuclear antibodies in juvenile rheumatoid arthritis. Arthritis Rheum. 1984;27(11):1286-9. [pmid: 6333875].
33 Siamopoulou-Mavridou A, Mavridis AK, Terzoglou C, et al. Autoantibodies in Greek juvenile chronic arthritis patients. Clin Exp Rheumatol. 1991;9(6):647-52. [pmid: 1764846].
34 Wakhlu A, Gupta D, Aggarwal A, et al. Low levels of anti-histone antibodies in north Indian children with juvenile rheumatoid arthritis. Indian J Med Res. 2003;118:204-7. [pmid: 14723486].
35 Hanson V, Kornreich HK, Drexler E. Rheumatoid factor in children with lupus erythematosus. A serologic study. Am J Dis Child. 1966;112(1):28-32. [pmid: 4951359].
36 Eichenfield AH, Athreya BH, Doughty RA, et al. Utility of rheumatoid factor in the diagnosis of juvenile rheumatoid arthritis. Pediatrics. 1986;78(3):480-4. [pmid: 3748683].
37 Andersson GB, Fasth A. Serum concentration of hyaluronan, IgM and IgA rheumatoid factors in a population based study of juvenile chronic arthritis. Scand J Rheumatol. 1994;23(4):183-90. [pmid: 8091143].
38 Balogh Z, Meretey K, Falus A, et al. Serological abnormalities in juvenile chronic arthritis: a review of 46 cases. Ann Rheum Dis. 1980;39(2):129-34. [pmid: 6966908].
39 Egeskjold EM, Permin H, Horbov S, et al. Anti-IgG antibodies in juvenile rheumatoid arthritis. Acta Paediatr Scand. 1981;70(5):711-6. [pmid: 7034456].
40 Ferreira RA, Silva CHM, Silva DAO, et al. Is measurement of IgM and IgA rheumatoid factors (RF) in juvenile rheumatoid arthritis clinically useful?. Rheumatol Int. 2007;27(4):345-9. [pmid: 17009016].
41 Permin H, Egeskjold EM. IgE anti-IgG antibodies in patients with juvenile and adult rheumatoid arthritis including Felty’s syndrome. Allergy. 1982;37(6):421-7. [pmid: 6982625].
42 Roizenblatt S, Goldenberg J, Gabriel A Jr, et al. 7S IgG rheumatoid factor and hidden 19S IgM rheumatoid factor in juvenile chronic arthritis. Allergol Immunopathol. 1993;21(5):197-200.
43 Taseski B, Dezelic N, Dezelic G, et al. A study of rheumatoid factors in juvenile rheumatoid arthritis (chronic polyarthritis) by the photometric latex test. Z Rheumatol. 1981;40(1):17-20. [pmid: 7223078].
44 Varbanova BB, Baleva M, Nikolov K, et al. Prevalence of IgM-, IgA- and IgG-rheumatoid factors in seronegative polyarticular disease compared to pauciarticular disease in juvenile chronic arthritis as measured by ELISA. Adv Exp Med Biol. 1999;455:61-8. [pmid: 10599324].
45 Wernick R, LoSpalluto JJ, Fink CW, et al. Serum IgG and IgM rheumatoid factors by solid phase radioimmunoassay. A comparison between adult and juvenile rheumatoid arthritis. Arthritis Rheum. 1981;24(12):1501-11. [pmid: 6798978].
46 Egeskjold EM, Johansen A, Permin H, et al. The significance of antinuclear antibodies in juvenile rheumatoid arthritis associated with chronic bilateral iridocyclitis. Acta Paediatr Scand. 1982;71(4):615-20. [pmid: 6982590].
47 Saulsbury FT. Prevalence of IgM, IgA and IgG rheumatoid factors in juvenile rheumatoid arthritis. Clin Exp Rheumatol. 1990;8(5):513-7. [pmid: 2261713].
48 Avcin T, Cimaz R, Falcini F, et al. Prevalence and clinical significance of anti-cyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. Ann Rheum Dis. 2002;61(7):608-11. [pmid: 12079901].
49 Brunner JK, Sitzmann FC. Anticyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. Mod Rheumatol. 2006;16(6):372-5. [pmid: 17164999].
50 Ferucci ED, Majka DS, Parrish LA, et al. Antibodies against cyclic citrullinated peptide are associated with HLA-DR4 in simplex and multiplex polyarticular-onset juvenile rheumatoid arthritis. Arthritis Rheum. 2005;52(1):239-46. [pmid: 15641089].
51 Kwok JSY, Hui KH, Lee TL, et al. Anticyclic citrullinated peptide: diagnostic and prognostic values in juvenile idiopathic arthritis and rheumatoid arthritis in a Chinese population. Scand J Rheumatol. 2005;34(5):359-66. [pmid: 16234183].
52 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnotic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
53 Whiting P, Rutjes AW, Reitsma JB, et al. Sources of variation and bias in studies of diagnostic accuracy: a systemic review. Ann Intern Med. 2004;140:189-202. [pmid: 14757617].
54 Pai M, Flores LL, Pai N, et al. Diagnostic accuracy of nucleic acid amplication tests for tuberculous meningitis: A systematic review and meta-analysis. Lancet Infect Dis. 2003;3:633-43. [pmid: 14522262].
55 Tan EM, Cohen AS, Fries JF, et al. The 1982 revised criteria for the classification of systemic lupus erythematosus. Arthritis Rheum. 1982;25:1271-7. [pmid: 7138600].
56 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Ann Intern Med. 2003;138(1):W1-W12. [pmid: 12513067].
57 Jacewicz M. Symptoms and diagnosis of musculoskeletal disorders. MERCK. 2006. www.merck.com/mmhe/sec05/ch059/ch059b.html.
58 de Inocencio J. Musculoskeletal pain in primary pediatric care analysis of 1000 consecutive general pediatric clinic visits. Pediatrics. 1998;102(6):e63. [pmid: 9832591].
59 McGhee JL, Burks FN, Sheckels JL, et al. Identifying children with chronic arthritis based on chief complaints: absence of predictive value for musculoskeletal pain as an indicator of rheumatic disease in children. Pediatrics. 2002;110(2:Pt 1):9.
60 Petty RE, Laxer RM. Textbook of pediatric rheumatology. 5 ed. Philadelphia. Elsevier. 2005.
61 Malleson PN, Fung MY, Rosenburg AM. The incidence of pediatric rheumatic diseases: result from the Canadian Pediatric Rheumatology Association Disease Registry. J Rheumatol. 1996;23:1981-7. [pmid: 8923379].
62 Kamphuis S, Silverman ED. Prevalence and burden of pediatric-onset systemic lupus erythematosus. Nat Rev Rheumatol. 2010;6(9):538-46. [pmid: 20683438].
63 Hochberg MC. Updating the American College of Rheumatology revised criteria for the classification of systemic lupus erythematosus [letter]. Arthritis Rheum. 1997;40:1725. [pmid: 9324032].
64 Benseler SM, Silverman ED. Systemic lupus erythematosus. Pediatr Clin N Amer. 2005;52:443.
65 Sahwney S, Woo P. Diagnosis and management of juvenile idiopathic arthritis: current status. Indian Pediatr. 2001;38:1083-90. [pmid: 11677297].
66 Hayward K, Wallace CA. Recent developments in anti-rheumatic drugs in pediatrics: treatment of juvenile idiopathic arthritis. Arthritis Res Ther. 2009;11(1):216-27. [pmid: 19291269].
67 Petty RE, Southwood TR, Manners P, et al. International League of Associations for Rheumatology Classification of Juvenile Idiopathic Arthritis: Second Revision, Edmonton, 2001. J Rheumatol. 2004;31(2):390-2. [pmid: 14760812].
68 Brewer EJ, Bass J, Baum J, et al. Current proposal revision of JRA criteria. Arthritis Rheum. 1977;20(Suppl 2):189-90.
69 EULAR. European League Against Rheumatism Bulletin No. 4: nomenclature and classification of arthritis in children. 1977.
70 Fabien N, Olsson NO, Goetz J, et al. Prevalence of autoantibodies to cyclic citrullinated peptide in patients with rheumatic diseases other than rheumatoid arthritis: a French multicentre study. Clinic Rev Allerg Immunol. 2008;34:34-44.
71 Niewold TB, Harrison MJ, Paget SA. Anti-CCP antibody testing as a diagnostic and prognostic tool in rheumatoid arthritis. Q J Med. 2007;100:193-201.
72 American College of Rheumatology. Position statement on methodology of testing for antinuclear antibodies. American College of Rheumatology. 2009. www.rheumatology.org/practice/clinical/position/ana_position_stmt.pdf#search=“methodologyoftestingforantinuclear”. Accessed February 3, 2011.
73 Vaile JH, Dyke L, Kherani R, et al. Is high titre ANA specific for connective tissue disease?. Clin Exp Rheumatol. 2000;18(4):433-8. [pmid: 10949716].
74 Keren DF. Antinuclear antibody testing. Clin Lab Med. 2002;22(2):447-74. [pmid: 12134471].
75 Syed RH, Gilliam BE, Moore TL. Rheumatoid factors and anticyclic citrullinated peptide antibodies in pediatric rheumatology. Curr Rheumatol Rep. 2008;10:156-63. [pmid: 18460272].
76 Lee AN, Beck CE, Hall HM. Rheumatoid factor and anti-CCP autoantibodies in rheumatoid arthritis: a review. Clin Lab Sci. 2008;21:15-8. [pmid: 18335856].
77 Masson-Bessiere C, Sebbag M, Girbal-Neuhauser E, et al. The major synovial targets of the rheumatoid arthritis-specific antifilaggrin autoantibodies are deiminated forms of the alpha- and beta-chains of fibrin. J Immunol. 2001;166(6):4177-84. [pmid: 11238669].
78 Leeflang MMG, Deeks JJ, Gatsonis C, et al. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-97. [pmid: 19075208].
79 Haraldstad K, Sorum R, Eide H, et al. Pain in children and adolescents: prevalence, impact on daily life, and parents' perception, a school survey. Scand J Caring Sci. 2010. [doi: 10.1111/j.1471-6712.201000785.x].
80 Perquin CW, Hazebroek-Kampschreur AA, Hunfeld JA, et al. Pain in children and adolescents: a common experience. Pain. 2000;87:51-8. [pmid: 10863045].
81 Roth-Isigkeit A, Thyen U, Raspe HH, et al. Reports of pain among German children and adolescents: an epidemiological study. Acta Paediatr. 2004;93:258-63. [pmid: 15046285].
82 Brattberg G. Do pain problems in young school children persist into early adulthood? A 13-year follow-up. Eur J Pain. 2004;8:187-99. [pmid: 15109969].
83 Manchikanti L, Singh V, Datta S, et al. Comprehensive review of epidemiology, scope, and impact of spinal pain. Pain Physician. 2009;12:E35-E70. [pmid: 19668291].
84 Diepenmaat AC, van der Wal MF, de Vet HC, et al. Neck/shoulder, low back, and arm pain in relation to computer use, physical activity, stress, and depression among Dutch adolescents. Pediatrics. 2006;117(2):412-6. [pmid: 16452360].
85 Olsen TL, Anderson RL, Dearwater SR, et al. The epidemiology of low back pain in an adolescent population. Am J Public Health. 1992;82:606-8. [pmid: 1532116].
86 Sundblad GMB, Saartok T, Engstrom LM. Prevalence and co-occurrence of self-rated pain and perceived health in school-children: age and gender differences. Eur J Pain. 2007;11(2):171-80. [pmid: 16542860].
87 Jarvis JN. Commentary - ordering lab tests for suspected rheumatic disease. Pediatr Rheumatol. 2008;6(19):1-3.
88 Jarvis JN. The unique clinical presentation of children with chronic arthritis: putting the pediatrics in pediatric rheumatology. Curr Prob Pediatr Adolesc Health Care. 2006;36:80-2.
89 Cuesta I, Kerr KL, Jarvis JN. Subspecialty referrals for pauciarticular juvenile rheumatoid arthritis. Arch Pediatr Adolesc Med. 2000;154(2):122-5. [pmid: 10665597].
90 Sherry DD, Bohnsack J, Salmonson K, et al. Painless juvenile rheumatoid arthritis. J Pediatr. 1990;116(6):921-3. [pmid: 2348295].
91 Salminen JJ, Erkintalo MO, Pentti J, et al. Recurrent low back pain and early disc degeneration in the young. Spine. 1999;13:1316-21. [pmid: 10404573].
92 Mikkelsson M. Musculoskeletal pain and fibromyalgia in preadolescents: prospective 1-year follow-up study. Turun yliopisto. Sarja D Osa. 1998:320.
93 Cook CD, Wedgwood RJP, Craig JM, et al. Systemic lupus erythematosus. Description of 37 cases in children and a discussion of endocrine therapy in 32 of the cases. Pediatrics. 1960;26:570. [pmid: 13695232].
94 Urbach F. Lupus erythematosus. Pediatr Clin N Amer. 1961;8:873.