# Peer Reviewers

Donald Bloch, M.D.

Massachusetts General Hospital and Harvard Medical School

Boston, MA

Peter Chira, M.D., M.S.

Stanford University School of Medicine

Stanford, CA

David F. Keren, M.D.

Warde Medical Laboratory

Ann Arbor, MI

Sampath Prahalad, M.B.B.S. (M.D.), M.S.

Emory University School of Medicine

Atlanta, GA

Sarah Ringold, M.D., M.S.

University of Washington School of Medicine and Seattle Children’s Hospital

Seattle, WA

Penny Whiting, Ph.D.

Faculty of Medicine and Dentistry

University of Bristol

Bristol, U.K.