# Methods

## Topic Development and Refinement

In this chapter we document a prospectively developed protocol that was used to conduct this comparative effectiveness review. A core research team was assembled by the University of Alberta Evidence-based Practice Center. In consultation with the Agency for Healthcare Research and Quality (AHRQ), a panel of key informants was created to provide input in the development of the Key Questions (KQs) and scope of the evidence report. The public was invited to comment on these KQs over a period of 1 month. After reviewing the public comments, the KQs were finalized and submitted to AHRQ for approval. A technical expert panel was subsequently created to provide content and methodological expertise throughout the development of the comparative effectiveness review.

### Search Strategy

The research librarian, in collaboration with the investigative team, developed and implemented search strategies designed to identify evidence relevant to questions of diagnostic performance and clinical impact of the tests (Appendix B).

KQs 1 and 2, the answers to which serve as background information, were addressed using a narrative approach by locating and summarizing information on the related disease prevalence, incidence, and natural history from the main search (described below) and additional searches using MEDLINE^®^ and Google Scholar. As the primary of focuses of this report, KQs 3, 4, and 5 were addressed by a rigorous systematic review process including a comprehensive search of the following electronic databases: MEDLINE^®^, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Embase, CINAHL^®^, Science Citation Index Expanded^®^ and Social Sciences Citation Index^®^ (both via Web of Science^®^), Academic Search Complete, Proquest Dissertations & Theses, and OCLC PapersFirst. We applied a diagnostic search filter and a child filter, when applicable. We conducted the original searches from 1960 to January 2010, and updated them in December 2010 and September 2011.

Search terms were identified by reviewing search strategies of systematic reviews on similar topics and by examining how potentially relevant studies were indexed in various databases (Appendix B). A combination of subject headings and text words was adapted for each electronic resource: (arthritis OR “lupus erythematosus” OR pain OR fibromyalgia OR “benign joint hypermobility” OR “joint instability” OR “patellofemoral pain syndrome” OR “arthralgia” OR “limb pain” OR “synovitis” OR “JIA” OR “JRA” OR “JSLE” OR “joint swelling”) AND (child* OR infant* OR kid* OR toddler* OR adoles* OR teen* OR pubescen* OR puberty* OR p?ediatric) AND (screening OR “natural history” OR “incidence” OR “prevalence” OR “referral” OR diagnosis OR “predictive value of tests” OR “reproducibility of results” OR “sex factors” OR “age factors” OR anxiety OR comorbidity) AND (“ANA test” OR “FANA test” OR “antinuclear antibod*” OR “rheumatoid factor*” OR “cyclic citrulline peptide” OR “anticycliccitrullinated peptide” OR “anti-CCP” ).

In addition to the searches of electronic databases, we searched the following conference proceedings and scientific meetings: American College of Rheumatology, Joint meeting of the British Society for Rheumatology, Canadian Rheumatology Association, European League Against Rheumatism, International League of Associations for Rheumatology, and American Academy of Pediatrics from 2005 to 2010. Additionally, we searched the bibliographies of the included studies and reviews for relevant studies. We set up search alerts for PubMed and Web of Science to identify any new and potentially relevant studies during the course of the review.

Results from the literature searches were entered into a Thomson Reuters Reference Manager 11.0.1^®^ bibliographic database.

### Study Selection

A two-stage selection was carried out. For the initial broad screening stage, each article was screened by two independent reviewers who assessed the relevance of the study based on its title and abstract using prespecified broad screening criteria. We excluded articles if they were judged clearly as (1) not primary studies reporting on prevalence of conditions, diagnostic test accuracy, or clinical impact, (2) not ANA, RF, or CCP tests, or (3) did not include a pediatric population. Articles were rated as “include,” “exclude,” or “unsure.” The full text of studies rated as “include” or “unsure” by both reviewers were retrieved. Discrepancies in decisions between reviewers were resolved through discussion or third party adjudication, if needed.

For the second level of screening the full-text of each article was further examined by two independent reviewers using a standard inclusion/exclusion form (Appendix C). This form was based on a specific and comprehensive set of criteria (Table 1). Each reviewer rated the article as “include,” “exclude,” or “unsure.” There was no restriction on study design, language, or publication year. The minimal requirement for inclusion was that studies must have recruited a population comprised of children and adolescents aged 18 years or less, examined the appropriate tests and reference standards, and provided information on (1) sensitivity (Sn) and specificity (Sp) or (2) clinically important outcomes. Discrepancies between the reviewers were resolved through discussion or third party adjudication, if needed. The corresponding author of the article was contacted when additional information was needed for making the inclusion/exclusion decisions.

Table 1 Inclusion and exclusion criteria

Article Type | - Studies reporting original research; - Any language; - No restriction on publication year, except studies of ANA published before 1980 (excluded because detection methods using animal substrates are no longer considered valid)
Participants | - Studies providing separate data for a population comprising children (≤18 years) with undiagnosed MSK pain or joint swelling, a diagnosis of pSLE or JIA, or index test results (i.e., ANA, RF, CCP)
Study Design | - Studies of any design that included at least 2 participants
Index Tests | - ANA, RF, CCP; - The assay method of ANA using animal substrate was excluded (pre-1980 methodology); - The test of hidden RF was excluded (proposed as an alternate to RF in JIA in 1970s but does not relate to conventional RF tests)
Reference Standard | - Diagnosis of pSLE or JIA based on clinical criteria
Outcomes | - For KQ 3 and 4: Studies providing sufficient data to calculate Sn and Sp; - For KQ 5: Studies providing numerical data or a narrative description regarding referral decisions, additional tests ordered, clinical management, and patient and parent anxiety due to the clinical uncertainty or additional tests

ANA = antinuclear antibody; CCP = cyclic-citrullinated peptide; JIA = juvenile idiopathic arthritis; KQ = Key Question; MSK = musculoskeletal; RF = rheumatoid factor; pSLE = pediatric systemic lupus erythematosus; Sn = sensitivity; Sp = specificity

### Data Extraction

Data were extracted by a single reviewer using a standard data extraction form and verified by a second reviewer. Any disagreements were resolved through discussion or third party adjudication, if needed. We extracted data for the following categories: study characteristics, participant characteristics, index test, reference standard, and outcomes.

### Quality Assessment

We assessed the methodological quality of each study using the QUADAS checklist.7 The tool assesses important common biases in diagnostic studies including spectrum, incorporation, and verification biases (Appendix C). Spectrum bias occurs when included patients do not represent the intended spectrum of severity for the target condition (i.e., JIA or pSLE).78 Incorporation bias occurs when the index test (i.e., ANA, RF, or CCP) is incorporated in the reference standard (e.g., ILAR or ACR criteria).78 Partial verification bias occurs when a nonrandom set of patients does not undergo the reference standard.78 Differential verification bias occurs when a set of patients is verified with a second reference standard, especially when this selection depends on the index test result.78 Disease progression bias occurs when the patient’s condition changes between administering the index test and the reference standard. Information bias occurs when the results of the index test are interpreted knowing the results of the reference standard, and vice versa.78

Two reviewers performed quality assessment independently. Decision rules regarding application of QUADAS were developed a priori. Discrepancies were resolved through discussion or third party adjudication, as needed.

### Data Analysis and Synthesis

We summarized the general characteristics of studies using descriptive statistics. For the diagnostic performance, we constructed 2×2 tables and calculated Sn, Sp, and positive and negative predictive values. For visual interpretation we presented the results in forest plots. An a priori decision was made to not conduct meta-analysis due to the expected large degree of heterogeneity in participant characteristics and test positive thresholds across studies. When data were available, subgroup analyses were conducted by accuracy modifiers, as well as by assay methods used and JIA onset-types.

### Rating the Body of Evidence

The strength of evidence was graded for KQs 3 to 5 using the AHRQ system for grading the strength of evidence (AHRQ Guidance for the Evaluation of Medical Tests (draft)).8 We assessed four domains including risk of bias, consistency, directness, and precision, and developed a summary of overall strength of evidence. The grading was done by two independent reviewers, and any discrepancy was resolved by discussion or third party adjudication, as needed. The “risk of bias” domain was scored as low, medium, or high risk of bias corresponding to the results of QUADAS; the “consistency” domain was scored as consistent, inconsistent, or unknown based on the visual interpretation of the forest plots; “directness” was scored as direct or indirect based on the relevance of the evidence to the corresponding KQ; “precision” was scored as precise or imprecise based on the width of 95 percent confidence intervals. The overall summary rating was evaluated as high, moderate, low, or insufficient.

### Applicability

Applicability refers to how generalizable the findings of this report are to a wider range of populations that vary by age, sex, clinical presentation, disease severity, and clinical setting. It was assessed according to the AHRQ Guidance for the Evaluation of Medical Tests (draft).8

### Peer Review and Public Commentary

Six experts in pediatric medicine, pediatric rheumatology, rheumatology, pathology, and diagnostic testing reviewed the draft report and provided feedback. Reviewer comments were considered by the University of Alberta Evidence-based Practice Center in preparation of the final report. All peer reviewer comments and the disposition of comments were submitted to AHRQ for assessment and approval.