# Subgroup Analyses by Onset Type of Juvenile Idiopathic Arthritis

Subgroup analysis of studies examining antinuclear antibody test for juvenile idiopathic arthritis (JIA; Figures G1 – G3). None of the studies provided subgroup data based on RF positivity for patients with polyarticular JIA.

Figure G1 Forest plot of sensitivity and specificity of antinuclear antibody test for oligoarticular juvenile idiopathic arthritis

Figure G1 is a forest plot of the sensitivity and specificity of antinuclear antibody test for oligoarticular juvenile idiopathic arthritis. It includes 5 studies: Fawcett 1999, Haynes 1986, Osborn 1984, S-Mavridou, and Wakhlu 2003. Sensitivity ranged from 0.00 (95% CI: 0.00, 0.07) in Wakhlu to 0.77 (95% CI: 0.67, 0.86) in Fawcett. Specificity ranged from 0.73 (95% CI: 0.60, 0.83) in Osborn, to 1.00 (95% CI: 0.86, 1.00) in Wakhlu.

Figure G2 Forest plot of sensitivity and specificity of antinuclear antibody test for polyarticular juvenile idiopathic arthritis

Figure G2 is a forest plot of the sensitivity and specificity of antinuclear antibody test for polyarticular juvenile idiopathic arthritis. It includes 5 studies: Fawcett 1999, Haynes 1986, Osborn 1984, S-Mavridou, and Wakhlu 2003. Sensitivity ranged from 0.03 (95% CI: 0.00, 0.11) in Wakhlu to 0.67 (95% CI: 0.56, 0.77) in Osborn. Specificity ranged from 0.73 (95% CI: 0.60, 0.83) in Osborn to 1.00 (95% CI: 0.86, 1.00) in Wakhlu.

Figure G3 Forest plot of sensitivity and specificity of antinuclear antibody test for systemic juvenile idiopathic arthritis

Figure G3 is a forest plot of the sensitivity and specificity of antinuclear antibody test for systematic juvenile idiopathic arthritis. It includes 5 studies: Fawcett 1999, Haynes 1986, Osborn 1984, S-Mavridou 1991, and Wakhlu 2003. Sensitivity ranged from 0.00 (95% CI: 0.00,0.12) in Wakhlu to 0.37 (95% CI: 0.16, 0.62) in S-Mavridou. Specificity ranged from 0.73 (95% CI: 0.60, 0.83) in Osborn to 1.00 (95% CI: 0.86, 1.00) in Wakhlu.

Subgroup analysis of studies examining IgM-RF test for JIA (Figures G4–G6). None of the studies provided subgroup data based on RF positivity for patients with polyarticular JIA.

Figure G4 Forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for oligoarticular juvenile idiopathic arthritis

Figure G4 is a forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for oligoarticular juvenile idiopathic arthritis. It includes 8 studies: Andersson-Gage 1994, Ferreira 2007, Haynes 1986, Lipinska 2008, Roizenblatt 1983, Saulsbury 1990, Varbanova 1999, and Wernick 1981. Sensitivity ranged from 0.03 (95% CI: 0.00, 0.18) in Wernick to 0.32 (95% CI: 0.16, 0.52) in Ferreira. Specificity ranged from 0.93 (95% CI: 0.82, 0.99) in Ferreira to 1.00 (0.94, 1.00) in Varbanova.

Figure G5 Forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for polyarticular juvenile idiopathic arthritis

Figure G5 is a forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for polyarticular juvenile idiopathic arthritis. It includes 8 studies: Andersson-Gage 1994, Ferreira 2007, Haynes 1986, Lipinska 2008, Roizenblatt 1983, Saulsbury 1990, Varbanova 1999, and Wernick 1981. Senisitivity ranged from 0.00 (95% CI: 0.00, 0.34) in Roizenblatt to 0.55 (95% CI: 0.32, 0.77) in Varbanova. Specificity ranged from 0.93 (95% CI: 0.82, 0.99) in Ferreira to 1.00 (95% CI: 0.94, 1.00) in Varbanova.

Figure G6 Forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for systemic juvenile idiopathic arthritis

Figure G6 is a forest plot of the sensitivity and specificity of IgM-rheumatoid factor test for systematic juvenile idiopathic arthritis. It includes 7 studies: Andersson-Gage 1994, Ferreira 2007, Haynes 1986, Lipinska 2008, Roizenblatt 1983, Saulsbury 1990, and Wernick 1981. Sensitivity ranged from 0.00 (95% CI: 0.00, 0.34) in Wernick to 0.44 (95% CI: 0.22, 0.69) in Haynes. Specificity ranged from 0.94 (95% CI: 0.79, 0.99) in Wernick to 1.00 (95% CI: 0.94, 1.00) in Varbanova.

Subgroup analysis of studies examining CCP test for JIA (Figures G7–G9). None of the studies provided subgroup data based on RF positivity for patients with polyarticular JIA.

Figure G7 Forest plot of sensitivity and specificity of cyclic-citrullinated peptide test for oligoarticular juvenile idiopathic arthritis

Figure G7 is a forest plot of the sensitivity and specificity of cyclic-citrullinated peptide test for oligoarticular juvenile idiopathic arthritis. It includes 6 studies: Avcin 2002, Ferucci 2005, Habib 2008, Kwok 2005, Lipinska 2008, and Mo 2008. Sensitivity range from 0.00 (95% CI: 0.00, 0.17) in Habib to 0.36 (95% CI: 0.21, 0.54) in Lipinska. Specificity ranged from 0.96 (95% CI: 0.80, 1.00) in Kwok to 1.00 (0.88, 1.00) in Avcin.

Figure G8 Forest plot of sensitivity and specificity of cyclic-citrullinated peptide test for polyarticular juvenile idiopathic arthritis

Figure G8 is a forest plot of the sensitivity and specificity of cyclic-citrullinated peptide test for polyarticular juvenile idiopathic arthritis. It includes 6 studies: Avcin 2002, Ferucci 2005, Habib 2008, Kwok 2005, Lipinska 2008, and Mo 2008. Sensivitiy ranges from 0.02 (95% CI: 0.00, 0.10) in Avcin to 0.43 (95% CI: 0.29, 0.58) in Lipinska. Specificity ranged from 0.96 (95% CI: 0.80, 1.00) in Kwok to 1.00 (95% CI: 0.88, 1.00) in Avcin.

Figure G9 Forest plot of sensitivity and specificity of cyclic-citrullinated peptide test for systemic juvenile idiopathic arthritis

Figure G9 is a forest plot of the sensitivity and specificity of cyclic-citrullinated peptide test for systematic juvenile idiopathic arthritis. It includes 6 studies: Avcin 2002, Ferucci 2005, Habib 2008, Kwok 2005, Lipinska 2008, and Mo 2008. Sensitivity ranged from 0.00 (95% CI: 0.00, 0.23) in Ferucci to 0.55 (0.23, 0.83) in Lipinska. Specificity ranged from 0.96 (95% CI: 0.80, 1.00) in Kwok to 1.00 (95% CI: 0.88, 1.00) in Avcin.