# Methodological Quality of Included Studies

Table E1 Methodological quality of studies evaluating an ANA test for pSLE in children with undiagnosed MSK pain

Author Year | Spectrum composition | Selection criteria | Reference standard | Test result definition | Disease progression bias | Partial verification | Differential verification | Incorporation bias | Index test execution | Test review bias | Reference standard bias | Uninterpretable results | Withdrawals
Fawcett29 1999 | No | No | Yes | Yes | U | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes
Wananukul30 2005 | No | Yes | Yes | Yes | U | Yes | Yes | No | Yes | Yes | Yes | Yes | No

U = unclear

Table E2 Methodological quality of studies evaluating an ANA test for JIA in children with undiagnosed MSK pain

Author Year | Spectrum composition | Selection criteria | Reference standard | Test result definition | Disease progression bias | Partial verification | Differential verification | Incorporation bias | Index test execution | Test review bias | Reference standard bias | Uninterpretable results | Withdrawals
Fawcett29 1999 | No | No | Yes | Yes | U | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes
Haynes31 1986 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | U | Yes | Yes | Yes
Jones32 2006 | No | No | U | Yes | U | Yes | U | Yes | No | U | Yes | Yes | No
Lipinska33 2008 | No | No | Yes | Yes | U | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes
Nordal34 2009 | No | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Osborn35 1984 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Siamopoulou-Mavridou36 1991 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Wakhlu37 2003 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes

U = unclear

Table E3 Methodological quality of studies evaluating a RF test for pSLE in children with undiagnosed MSK pain

Author Year | Spectrum composition | Selection criteria | Reference standard | Test result definition | Disease progression bias | Partial verification | Differential verification | Incorporation bias | Index test execution | Test review bias | Reference standard bias | Uninterpretable results | Withdrawals
Hanson38 1966 | U | No | Yes | U | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No

U = unclear

Table E4 Methodological quality of studies evaluating a RF (IgM) test for JIA in children with undiagnosed MSK pain

Author Year | Spectrum composition | Selection criteria | Reference standard | Test result definition | Disease progression bias | Partial verification | Differential verification | Incorporation bias | Index test execution | Test review bias | Reference standard bias | Uninterpretable results | Withdrawals
Andersson-Gare39 1994 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Balogh40 1980 | No | No | Yes | No | No | Yes | Yes | Yes | Yes | U | Yes | U | Yes
Egeskjold41 1981 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Egeskjold49 1982 | No | No | Yes | U | No | Yes | Yes | Yes | Yes | U | U | Yes | Yes
Eichenfield48 1986 | Yes | No | Yes | Yes | U | Yes | Yes | Yes | U | Yes | U | Yes | U
Ferreira42 2007 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | U | Yes
Hanson38 1966 | No | No | Yes | U | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No
Haynes31 1986 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | U | Yes | Yes | Yes
Lipinska33 2008 | No | No | Yes | Yes | U | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes
Permin43 1982 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Roizenblatt44 1993 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Saulsbury50 1990 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Siamopoulou-Mavridou36 1991 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Taseski45 1981 | No | No | No | No | U | U | U | Yes | U | Yes | Yes | Yes | Yes
Varbanova46 1999 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Wernick47 1981 | No | No | Yes | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes

U = unclear

Table E5 Methodological quality of studies evaluating a CCP test for JIA in children with undiagnosed MSK pain

Author Year | Spectrum composition | Selection criteria | Reference standard | Test result definition | Disease progression bias | Partial verification | Differential verification | Incorporation bias | Index test execution | Test review bias | Reference standard bias | Uninterpretable results | Withdrawals
Avcin 2002 51 | No | No | U | Yes | U | Yes | U | Yes | Yes | Yes | Yes | Yes | Yes
Brunner 2006 52 | No | No | U | Yes | U | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes
Ferucci 2005 53 | No | Yes | Yes | Yes | No | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes
Habib 2008 54 | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | U | Yes
Kasapcopur 2004 55 | No | U | Yes | Yes | No | Yes | Yes | Yes | No | U | Yes | Yes | Yes
Kwok 2005 56 | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | U | Yes | Yes | Yes
Lipinska 2008 33 | No | No | Yes | Yes | U | Yes | Yes | Yes | U | Yes | Yes | Yes | Yes

U = unclear